# List of Acronyms/Abbreviations

ADH: Atypical Ductal Hyperplasia
AHRQ: Agency for Healthcare Research and Quality
ALH: Atypical Lobular Hyperplasia
BI-RADS^®^: Breast Imaging Reporting and Data System
CI: Confidence Interval
DCIS: Ductal Carcinoma In Situ
FN: False Negative
FP: False Positive
G: Gauge
LCIS: Lobular Carcinoma In Situ
MRI: Magnetic Resonance Imaging
NA: Not Applicable
NR: Not Reported
TN: True Negative
TP: True Positive
UK: United Kingdom
US: Ultrasound
USA: United States of America