# Acknowledgments

The Evidence-based Practice Center would like to thank Eileen Erinoff, M.S.L.I.S, and Helen Dunn for providing literature retrieval and documentation management support and Lydia Dharia for her assistance with the final preparations of the report.

## Technical Expert Panel

- Wendie Berg, M.D., Ph.D.
- American College of Radiology Representative

- Patty Carney, Ph.D.
- Oregon Health and Science University

- Richard E. Fine, M.D., FACS
- Advanced Breast Care of Georgia

- Bev Parker, Ph.D.
- Y-ME National Breast Cancer Organization

- Maria Wetzel, B.S.
- National Breast Cancer Coalition

- Bonnie Yankaskas, Ph.D., M. P. H.
- University of North Carolina

- R. James Brenner, M.D., J.D., FACR, FCLM
- University of California San Francisco

- Joanne Elmore, M.D., M.P.H.
- University of Washington

- Carol Lee, M.D.
- Yale University School of Medicine

- Elizabeth Steiner
- Oregon Health and Science University

- Pamela Wilcox
- American College of Radiology Representative

## AHRQ Contacts

- Beth Collins-Sharp, Ph.D., R.N.
- Director
- Evidence-based Practice Center Program
- Agency for Healthcare Research and Quality
- Rockville, MD

- Shilpa H. Amin, M.D., M.Bsc., FAAFP
- Task Order Officer
- Evidence-based Practice Center Program
- Agency for Healthcare Research and Quality
- Rockville, MD