# Results

## Results of Literature Searches for Key Questions

We identified 6583 nonduplicative titles or abstracts with potential relevance, with 554 proceeding to full text review (Figure 2). We excluded 469 studies at full text review. We included 68 unique studies (85 publications) in the review. In addition to these 68 studies included since the completion of our original review of therapies for children with autism spectrum disorder (ASD) in 2011,^11^ we include 12 comparative studies addressed in the 2011 review that also addressed an agent used in the current review. Four studies (reported in multiple publications) included in the 2011 review now include followup analyses published since the completion of that report.^15–39^ We outline findings from all 76 studies below.

Figure 2 Disposition of studies identified for this review

Figure 2 outlines the disposition of studies identified for this review. We identified 6583 nonduplicative titles or abstracts with potential relevance, with 554 proceeding to full text review. We excluded 469 studies at full text review. We included 68 unique studies publications in the review. We also include summaries of 12 comparative studies of medical approaches addressed in our earlier review of therapies for children with ASD (Warren et al. 2011).

### Description of Included Studies

The 76 studies included in the review comprised 72 randomized controlled trials (RCTs) reported in multiple publications,^15–119^ two nonrandomized trials,^120, 121^ and two retrospective cohort studies.^122, 123^ Among the 65 studies clearly reporting a funding source, 12 were industry-sponsored,^15–21, 40–44, 48, 51–53, 67, 75, 101, 108, 112, 113, 115^ and the remainder were funded by government health agencies, foundations, or universities.

We considered 39 studies to have low risk of bias,^15–39, 41–46, 48–55, 57, 58, 60, 67, 73–76, 78, 81, 83, 89–100, 102, 108, 110, 111, 114^ 29 to have moderate,^40, 47, 59, 63, 66, 68–72, 77, 79, 80, 82, 84–87, 101, 103, 106, 107, 109, 112, 113, 115–118, 121, 122, 124^ and eight to have high risk.^56, 61, 62, 64, 65, 88, 104, 105, 120, 123^ Despite the high number of low and moderate risk of bias studies, few studies addressed the same interventions or outcomes, and most studies included few participants, evaluated only in the short term (<6 months); thus, evidence for many agents remains insufficient. Table 5 outlines key study characteristics. Because few studies addressed sub-questions under Key Questions (KQ) 1 and 2, we present results in the aggregate under each of these KQ.

Table 5 Overview of studies

Characteristic | RCTs (n=72) | Nonrandomized Trials (n=2) | Retrospective Cohort Studies (n=2) | Total Literature
Intervention category
Antipsychotics | 11 | 0 | 1 | 12
Medications used to treat ADHD | 5 | 0 | 0 | 5
Combined medical and behavioral approaches | 3 | 2 | 0 | 5
Nutrition and diet | 19 | 0 | 0 | 19
Risperidone adjuncts | 14 | 0 | 0 | 14
Hyperbaric oxygen therapy | 3 | 0 | 0 | 3
N-acetylcysteine | 2 | 0 | 0 | 2
Tetrahydrobiopterin | 2 | 0 | 0 | 2
Other medical approaches^a^ | 13 | 0 | 1 | 14
Treatment duration
<1–4 weeks | 7 | 1 | 0 | 8
5–8 weeks | 15 | 0 | 0 | 15
9–12 weeks | 28 | 1 | 0 | 29
13–20 weeks | 5 | 0 | 0 | 5
21–36 weeks | 13 | 0 | 1 | 14
>52 weeks | 4 | 0 | 1 | 5
Region of study conduct
Africa | 2 | 0 | 0 | 2
Asia | 23 | 2 | 0 | 25
Australia | 3 | 0 | 0 | 3
Europe | 11 | 0 | 0 | 11
North America | 33 | 0 | 2 | 35
Risk of bias
Low | 39 | 0 | 0 | 39
Moderate | 27 | 1 | 1 | 29
High | 6 | 1 | 1 | 8
Total N participants | 3902 | 102 | 186 | 4190

a Includes two of donepezil and one each of neurostimulation, amantadine, divalproex, stem cell transplantation, melatonin, bumetanide, oxytocin, mecamylamine, prednisolone, and citalopram.

ADHD = attention deficit hyperactivity disorder; N = number; RCT = randomized controlled trial

Table 6 outlines key outcomes addressed by studies evaluating each intervention class. Challenging behaviors and symptom severity were frequently targeted. All studies reported harms.

Table 6 Key outcomes targeted in studies of medical interventions

Intervention Category/Outcome | Challenging Behavior | ASD Symptom Severity | Repetitive Behavior | Attention/ADHD Symptoms | Adaptive Behavior | Communication | Medical Symptoms (e.g., Sleep, GI) | Neurocognitive Skills | Repetitive Behavior | Social Skills | Harms
Antipsychotics^15–21, 28–39, 47–52, 101, 102, 109, 112, 113, 122^ | X | X | X | X | X | | | | X | | X
ADHD medications^24–27, 40–46^ | X | X | X | X | X | X | | X | X | | X
Combination medical and behavioral treatments^54, 55, 57, 120, 121^ | X | X | | X | | | | X | | | X
Omega-3 fatty acids^80–82, 84^ | X | X | | | X | X | | | | X | X
Specialized diets^58–65, 104–107^ | X | X | | X | | X | X | X | | | X
Nutritional supplements^83, 85–88, 117^ | X | X | | X | | X | | X | | | X
Risperidone adjuncts^47, 89–100, 118, 124^ | X | X | | | | | | | | | X
Hyperbaric oxygen^66, 67, 114^ | X | X | | | X | X | | X | | X | X
N-acetylcysteine^78, 79^ | X | X | X | | | X | | | X | X | X
Tetrahydrobiopterin^53, 103^ | X | X | | X | X | X | | | | X | X
Other medical treatments^22, 23, 56, 68–75, 77, 101, 108, 115, 116, 123^ | X | X | X | X | X | X | X | X | X | X | X

ADHD = attention deficit hyperactivity disorder; ASD = autism spectrum disorder

### Gray Literature

Our searches of ClinicalTrials.gov and other trial registers did not yield additional eligible studies for the review. We did not receive information in response to requests for scientific information from manufacturers or device makers. We used information from organization web sites searched to provide additional context for the discussion section of the report.

## KQ1 Benefits and Harms of Medical Treatments

### Studies of Antipsychotics

#### Key Points

- Five RCTs addressing risperidone reported significant improvements in measures of irritability and other challenging behaviors in the treatment group compared with placebo in the short-term (≤6 months), with continued positive effects over a mean 21-month treatment period in an uncontrolled extension study. Side effects including somnolence and weight gain were clinically significant.
- Two RCTs of aripiprazole reported statistically significant improvements in irritability and challenging behavior in the treatment groups compared with placebo over 8 weeks of treatment and maintenance of improvements in a 52-week uncontrolled extension. Harms were also clinically significant. Another RCT reported no differences in time to relapse (return of significant negative symptoms) between children taking aripiprazole versus placebo; quality of life measures also did not differ between groups.
- Three small studies comparing risperidone with aripiprazole reported no significant differences in effects on challenging behaviors or general improvement; one study noted no significant differences in weight gain associated with each agent.
- One small RCT reported greater improvements in challenging behavior with risperidone vs. haloperidol, and one comparing risperidone and memantine and reported no group differences on any outcomes.
- Risperidone and aripiprazole improved challenging behaviors in the short-term (<6 months), with clinically significant harms. Our confidence in these conclusions is high (high strength of evidence). Behaviors improved in the longer term (≥6 months) with these agents compared with placebo, but our confidence in this conclusion is low (low strength of evidence) as few studies had longer-term followup.
- In studies comparing risperidone and aripiprazole, BMI increased with both drugs over treatment durations of 6 months to more than 2 years, but group differences were not significant. We have low confidence in this conclusion given the few studies addressing this outcome (low strength of evidence).
- Other outcomes (e.g., challenging behaviors, attention) were not consistently addressed; thus we considered strength of evidence insufficient for all other intervention/outcome pairs.

#### Overview of the Literature

We identified 11 unique RCTs (reported in multiple publications and including comparative studies identified for the current review and those reported in our 2011 review^11^) addressing antipsychotics^15–21, 28–39, 47–52, 101, 102, 109, 111–113^ and one retrospective cohort that reported harms data only.^122^ Seven studies had low risk of bias,^15–21, 28–39, 48–52, 102, 112, 113^ and five had moderate risk.^47, 101, 109, 112, 113, 122^ Studies included a total of 1055 children ranging in age from 2 to 20 years and were conducted in the United States (n=5), Iran (n=2), and one each in Canada, Turkey, Italy, the Netherlands, and India.

Two RCTs addressed aripiprazole compared with placebo;^15–21, 48^ five addressed risperidone compared with placebo;^28–39, 51, 52, 102, 109, 111–113^ and two compared risperidone and aripiprazole.^49, 50^ A retrospective cohort compared these agents and reported differences in weight gain.^122^ One RCT compared risperidone and haloperidol,^101^ while another compared risperidone and memantine.^47^

Five of these eight RCTs were also included in our 2011 review,^15–21, 28–39, 52, 109, 111–113, 125^ and investigators of four of these studies have published additional analyses of participants included in the original trials. These studies included two “families” of papers that report post-hoc and additional or combined analyses of participants in the initial trials. The first family of studies, conducted by Research Units on Pediatric Psychopharmacology (RUPP) Autism Network investigators, assessed risperidone and included an initial 8-week trial comparing risperidone and placebo in 101 children;^34^ one paper reporting potential moderators of effect in the 8-week trial;^29^ one paper reporting parent concerns assessed during the initial 8-week trial;^35^ one paper reporting social interaction measures in these participants^39^ and including data from a study (included in our 2011 review) that compared risperidone alone with risperidone plus parent training;^126^; one reporting measures of repetitive behavior^38^ and also including data from the risperidone plus parent training study^126^ and one paper that reported cognitive changes in a subset of children in the original 8-week trial.^30^ This family also includes another paper that assessed longer term (16 weeks) effects in children who responded to risperidone in the original 8-week trial plus children who originally received placebo and were considered placebo nonresponders but had subsequent positive response to risperidone (total n=63);^36^ 32 of these children went on to enroll in an RCT comparing either continued risperidone or risperidone with gradual placebo replacement.^31^ The investigators followed up these reports with a paper reporting additional social interaction and stereotypy analyses of the 101 original participants in the 8-week trial and the 63 participants in the extension trial,^32^ analyses of weight changes in the 63 children in the extension trial,^33^ and analysis of adaptive behavior measures in 48 of these 63 children for whom such data were available.^37^ Finally, the family includes a paper reporting longer term effects (mean 21 months) in 84 of the original 101 trial participants (38 of whom participated in the extension trial); among these 84 individuals, 53 continued to receive risperidone in the month before followup.^28^ Another paper reports changes in prolactin levels in these children after 8 weeks, 6 months, and roughly 22 months of risperidone treatment.^111^

The second family of papers assessed aripiprazole and includes one 8-week trial comparing fixed doses of aripiprazole with placebo;^20^ another 8-week trial comparing titrated doses of aripiprazole with placebo;^21^ one paper reporting safety data in these two original trials;^19^ another reporting health-related quality of life measures assessed in the two original trials;^17^ and another outlining Aberrant Behavior Checklist (ABC) data in the two trials.^16^ The family also includes as open label extension that combined children from the original RCTs (both treatment and placebo groups) and added children who had not participated in the prior studies (de novo subjects) and in which all 330 participants received 52 weeks of aripiprazole.^15^ Finally, this family includes a paper reporting adverse events/safety data for children in the 52-week open label extension.^18^

Across studies, treatment duration ranged from 8 weeks to over 2 years, with followup immediately post-treatment in all studies.

#### Detailed Analysis

The literature on antipsychotic effects in children with ASD reports a variety of outcomes but converges on the ABC, a rating scale completed by caregivers of individuals with ASD. Studies also typically assessed potential side effects or harms, including assessment of weight gain, somnolence, and gastrointestinal symptoms and used the Clinical Global Impression (CGI) rating scale. Studies of antipsychotics addressed either risperidone or aripiprazole and reported significant improvements in measures of challenging behavior in the short term (<6 months) in children receiving the medications compared with those receiving placebo. Harms of these agents, including extrapyramidal symptoms and weight gain, were also significant. Studies reporting longer term followup (up to 21 months for risperidone) reported continued effectiveness in most children but did not include control groups. We report brief summaries of outcomes reported in each study below and end of treatment outcomes on the ABC and CGI in Tables 7–10. Appendix F includes detailed summary tables outlining other outcomes.

Table 7 Key outcomes in studies comparing risperidone and placebo

Author, Year, Study Design Groups (Dose), N Enrollment/N Final Treatment Duration/Follow-Up Time Point Post-Treatment Risk Of Bias | Baseline Scores, Mean ± SD | Post-Treatment Scores, Mean ± SD
Scahill 2015^34^ RCT G1: Risperidone (up to 2.5 mg/kg), 49/49 G2: Placebo (NA), 52/52 8 weeks/EOT Moderate ROB | ABC-Irritability G1: 26.2 ± 7.9 G2: 25.5 ± 6.6 ABC-Lethargy/Social Withdrawal G1: 16.4 ± 8.2 G2: 16.1 ± 8.7 ABC-Stereotypic Behavior G1: 10.6 ± 4.9 G2: 9 ± 4.4 ABC-Hyperactivity G1: 31.8 ± 9.6 G2: 32.3 ± 8.5 ABC-Inappropriate Speech G1: 4.8 ± 4.1 G2: 6.5 ± 3.6 CGI-S – Moderate G1: 9 (18) G2: 9 (18) CGI-S – Marked G1: 27 (55) G2: 28 (57) CGI-S – Severe G1: 12 (24) G2: 12 (24) CGI-S – Extreme G1: 1 (2) G2: 0 (0) | ABC-Irritability G1: 11.3 ± 7.4 G2: 21.9 ± 9.5 G1 vs. G2: p<0.001; ES=1.2 ABC-Lethargy/Social Withdrawal G1: 8.9 ± 6.4 G2: 12 ± 8.3 G1 vs. G2: p=0.03, ES=0.4 ABC-Stereotypic Behavior G1: 5.8 ± 4.6 G2: 7.3 ± 4.8 G1 vs. G2: p<0.001 ES=0.8 ABC-Hyperactivity G1: 17 ± 9.7 G2: 27.6 ± 10.6 G1 vs. G2: p<0.001 ABC-Inappropriate Speech G1: 3 ± 3.1 G2: 5.9 ± 3.8 G1 vs. G2: p=0.03. ES=0.3 CGI-I – Much Improved or very much improved + 25% reduction on ABI-I G1: 34 (69) G2: 6 (12)
Scahill 2015^36^ RCT G1: Risperidone (2.5 mg/day), 63/63 G2: Placebo-Substitution (NA), NA 4 weeks during open label extension/EOT Moderate ROB | End of initial 8 wks of treatment exposure CGI-I – Very much improved G1: 19 (30.2) G2: ND CGI-I – Much Improved G1: 42 (66.7) G2: ND CGI-I Minimally Improved G1: 0 (0) G2: ND CGI-I – No Change G1: 2 (3.2) G2: ND CGI-I – Worse G1: 0 (0) G2: ND CGI-I – Much Worse G1: 0 (0) G2: ND ABC-Irritability G1: 9.5 ± 6.8 G2: ND ABC-Social Withdrawal/Lethargy G1: 7.3 ± 5.4 G2: ND ABC-Stereotypy G1: 4.9 ± 4.3 G2: ND ABC-Hyperactivity G1: 15.1 ± 10 G2: ND ABC-Inappropriate Speech G1: 3.4 ± 3.6 G2: ND | ABC-Irritability G1: 11.7 ± 8 G2: ND ABC-Social Withdrawal/Lethargy G1: 6.8 ± 5.9 G2: ND ABC-Stereotypy G1: 5.8 ± 4.7 G2: ND ABC-Hyperactivity G1: 15.8 ± 10.2 G2: ND ABC-Inappropriate Speech G1: 3.4 ± 3.2 G2: ND
Scahill 2015^28^ RCT G1: Risperidone (2.5 mg/day), 57/55 G2: Placebo (NA), 27/26 Mean 21 months/2 Years post-treatment Moderate ROB | ABC-Irritability G1: 27.22 ± 7.28 G2: 23.44 ± 7.24 ABC-Social Withdrawal G1: 16.05 ± 8.55 G2: 18.52 ± 9.72 ABC-Stereotypic Behavior G1: 10.5 ± 4.43 G2: 8.84 ± 5.22 ABC-Hyperactivity/Noncompliance G1: 34.3 ± 7.95 G2: 28.58 ± 10.4 ABC-Inappropriate Speech G1: 5.71 ± 3.93 G2: 5.59 ± 4.03 CGI-Severity G1: 5.09 0.7 G2: 5.23 0.65 | 2 years post-treatment ABC-Irritability G1: 14.82 ± 8.4 G2: 17.78 ± 10.82 G1 vs. G2: p=0.0147 ABC-Social Withdrawal G1: 8.43 ± 6.77 G2: 13.33 ± 8.73 G1 vs. G2: p=0.0130 ABC-Stereotypic Behavior G1: 6.02 ± 4.4 G2: 6.76 ± 5.37 G1 vs. G2: p=0.0866 ABC-Hyperactivity/Noncompliance G1: 17.68 ± 10.16 G2: 23.38 ± 12.06 G1 vs. G2: p=0.0020 ABC-Inappropriate Speech G1: 3.86 ± 3.01 G2: 5.15 ± 4.24 G1 vs. G2: p=0.0433 CGI-Severity G1: 4.4 ± 0.89 G2: 4.65 ± 1.09 G1 vs. G2: p=0.3004
Kent 2013^51, 52^ RCT G1: Risperidone (0.125–0.175 mg/day; low dose), 30/25 G2: Risperidone (1.25–1.75 mg/day; high dose), 31/25 G3: Placebo (NA), 35/27 6 weeks/EOT Low ROB | ABC-Irritability G1: 27.1 ± 6.26 G2: 28.0 ± 7.81 G3: 28.9 ± 6.10 CGI – Severity G1: 5.1 ± 0.92 G2: 5.0 ± 0.78 G3: 4.9 ± 0.67 | Mean change in: ABC-Irritability G1: −7.4 ± 8.12 G2: −12.4 ± 6.52 G3: −3.5 ± 10.67 G1 vs. G3: p=ns G2 vs. G3: p<0.001 CGI – Severity G1: −0.4 ± 0.73 G2: −1.0 ± 0.78 G3: −0.3 ± 0.79 G1 vs. G3: p=ns G2 vs. G3: p<0.001
| ABC-Irritability G1: 13.4 ± 3.99 G2: 14.4 ± 4.64 G3: 13.7 ± 2.66 ABC-Hyperactivity G1: 30.1 ± 11.46 G2: 33.8 ± 9.75 G3: 31.4 ± 8.60 ABC-Stereotypic Behavior G1: 9.3 ± 5.17 G2: 11.5 ± 5.06 G3: 10.5 ± 5.26 ABC-Inappropriate Speech G1: 6.6 ± 3.49 G2: 7.5 ± 2.78 G3: 5.9 ± 3.42 ABC-Social Withdrawal G1: 18.2 ± 9.71 G2: 21.4 ± 9.09 G3: 18.1 ± 10.16 CGI-Severity G1: 5.1 ± 0.93 G2: 5 ± 0.75 G3: 4.9 ± 0.67 | Mean change score ABC-Irritability G1: −13.2 ± 9.29 G2: −13 ± 10.55 G3: −11.8 ± 7.68 ABC-Hyperactivity G1: −10.5 ± 12.42 G2: −12.3 ± 11.78 G3: −11.7 ± 8.54 ABC-Stereotypic Behavior G1: −4.2 ± 6.51 G2: −4.6 ± 5.14 G3: −2.8 ± 4.12 ABC-Inappropriate Speech G1: −1.8 ± 3.93 G2: −2.1 ± 3.07 G3: −1.5 ± 2.69 ABC-Social Withdrawal G1: −8.3 ± 9.03 G2: −10.4 ± 8.57 G3: −6.9 ± 8.08 CGI-Severity G1: −1 ± 1.02 G2: −1.3 ± 1.17 G3: −0.9 ± 0.88 CGI-Much or Very Much Improved G1: 14 (58) G2: 15 (60) G3: 20 (69) G1 vs. G2 vs. G3: p=ns
Troost 2005^102^ RCT G1: Risperidone (0.5–3.5 mg/day), 12/12 G2: Placebo (ND), 12/12 8 weeks/EOT Low ROB | ABC-Irritability G1: 11.1 ± 8.1 G2: 12.7 ± 7.7 ABC-Social Withdrawal/Lethargy G1: 5 ± 6 G2: 6.7 ± 6.9 ABC-Stereotypic Behavior G1: 2.3 ± 3.2 G2: 4.7 ± 4.3 ABC-Hyperactivity G1: 16.8 ± 11.5 G2: 15.8 ± 9.4 ABC-Inappropriate Speech G1: 3.2 ± 3.2 G2: 2.3 ± 1.9 | ABC-Irritability G1: 12.6 ± 9.8 G2: 20.3 ± 10.2 G1 vs G2, p=0.043 ABC-Social Withdrawal/Lethargy G1: 2.8 ± 3.1 G2: 4.8 ± 3.5 G1 vs G2, p=ns ABC-Stereotypic Behavior G1: 3.3 ± 3.5 G2: 3.4 ± 4.6 G1 vs G2, p=0.305 ABC-Hyperactivity G1: 18 ± 11.8 G2: 20.8 ± 12.1 G1 vs G2, p=0.118 ABC-Inappropriate Speech G1: 3 ± 2.8 G2: 3 ± 2.3 G1 vs G2: p=0.303 CGI-Minimally Improved G1: 5 (42) G2: 3 (25) CGI-Much Improvement G1: 3 (25) G2: 6 (50) CGI-Very Much Improved G1: 4 (33) G2: 3 (25)
Shea 2004^112, 113^ RCT G1: Risperidone (0.02 mg/kg/day), 39/39 G2: Placebo (NA), 38/38 8 weeks/EOT Moderate ROB | ABC-Irritability G1: 18.9 ± 8.8 G2: 21.2 ± 9.7 ABC-Hyperactivity G1: 13.7 ± 7 G2: 14.3 ± 8.2 ABC-Social Withdrawal/Lethargy G1: 27.3 ± 9.7 G2: 30.9 ± 8.8 ABC-Stereotypy G1: 4.6 ± 3.4 G2: 4.8 ± 3.7 ABC-Inappropriate Speech G1: 7.9 ± 5 G2: 8.1 ± 5.6 | Mean Change Scores ABC-Irritability G1: −12.1 ± 5.8 G2: −6.5 ± 8.4 G1 vs. G2: p≤0.001 ABC-Hyperactivity G1: −8.6 ± 5.9 G2: −5.7 ± 6.9 G1 vs. G2: p≤0.01 ABC-Social Withdrawal/Lethargy G1: −14.9 ± 6.7 G2: −7.4 ± 9.7 G1 vs. G2: p≤0.001 ABC-Stereotypy G1: −2.6 ± 2.6 G2: −1.6 ± 3 G1 vs. G2: p≤0.05 ABC-Inappropriate Speech G1: −4.3 ± 3.8 G2: −2.4 ± 4 G1 vs. G2: p≤0.05

ABC = Aberrant Behavior Checklist; CGI-I = Clinical Global Impression Scale Improvement, EOT = end of treatment; ES = effect size; G = group; kg = kilograms; mg = milligrams; mL = milliliters; NA = not applicable; ND = no data; RCT = randomized controlled trial; ROB = risk of bias; SD = standard deviation

Table 8 Key outcomes in studies comparing aripiprazole and placebo

Author, Year, Study Design Groups (Dose), N Enrollment/N Final Treatment Duration/Follow-Up Time Point Post-Treatment Risk Of Bias | Baseline Scores, Mean ±SD | Post-Treatment Scores, Mean ± SD
Marcus 2011^20^ RCT G1: Aripiprazole (5 mg/kg), 53/44 G2: Aripiprazole (10 mg/kg), 59/49 G3: Aripiprazole (15 mg/kg), 54/47 G4: Placebo (NA), 52/38 8 weeks/EOT Moderate ROB | ABC-Irritability G1: 28.6 ± 7.6 G2: 28.2 ± 7.4 G3: 28.9 ± 6.4 G4: 28 ± 6.9 ABC-Hyperactivity/Noncompliance G1: 33.1 ± 1.4 G2: 33.7 ± 1.3 G3: 32.2 ± 1.4 G4: 31 ± 1.4 ABC-Stereotypic Behavior G1: 11.4 ± 0.8 G2: 11.6 ± 0.8 G3: 11.6 ± 0.8 G4:10.7 ± 0.8 ABC-Social Withdrawal/Lethargy G1: 17.7 ± 1.4 G2: 16.8 ± 1.3 G3: 18.9 ± 1.4 G4: 18 ± 1.5 ABC-Inappropriate Speech G1: 5.8 ± 0.6 G2: 6.8 ± 0.5 G3: 6.3 ± 0.5 G4: 5.9 ± 0.6 CGI-S G1: 5 ± 0.1 G2: 4.9 ± 0.1 G3: 5.1 ± 0.1 G4: 4.7 ± 0.1 | Change scores ABC-Irritability G1: −12.4 G2: −13.2 G3: −14.4 G4: −8.4 G1 vs. G4: p=0.032 G2 vs. G4: p=0.008 G3 vs. G4: p=0.001 ABC-Hyperactivity/Noncompliance G1: −14 ± 1.6 G2: −13.3 ± 1.5 G3: −16.3 ± 1.6 G4: −7.7 ± 1.7 G1 vs. G4: p≤0.005 G2 vs. G4: p≤0.05 G3 vs. G4: p≤0.001 ABC-Stereotypic Behavior G1: −4.5 ± 0.68 G2: −4.2 ± 0.63 G3: −4.5 ± 0.66 G4: −1.8 ± 0.69 G1 vs. G4: p≤0.005 G2 vs. G4: p≤0.05 G3 vs. G4: p≤0.005 ABC-Social Withdrawal/Lethargy G1: −5.8 ± 1.2 G2: −4.9 ± 1.1 G3: −7.9 ± 1.1 G4: −5.2 ± 1.2 ABC-Inappropriate Speech G1: −2 ± 0.5 G2: −1.8 ± 0.4 G3: −2.3 ± 0.4 G4: −1.1 ± 0.5 CGI-S G1: −0.9 ± 0.2 G2: −1 ± 0.1 G3: −1.1 ± 0.2 G4: −0.6 ± 0.2
Marcus 2011^21^ RCT G1: Aripiprazole (2–15 mg/kg), 47/39 G2: Placebo (NA), 51/36 8 weeks/EOT Moderate ROB | ABC-Irritability G1: 29.6 ± 6.4 G2: 30.2 ± 6.5 ABC-Hyperactivity/Noncompliance G1: 34.1 G2: 34.7 ABC-Stereotypic Behavior G1: 11.9 G2: 10.7 ABC-Inappropriate Speech G1: 7 G2: 7 | Change Scores ABC-Irritability G1: −12.9 G2: −5 G1 vs. G2: p<0.001 ABC-Hyperactivity/Noncompliance G1: −12.7 G2: −2.8 G1 vs. G2: p<0.001 ABC-Stereotypic Behavior G1: −4.8 G2: −2 G1 vs. G2: p<0.001 ABC-Inappropriate Speech G1: −2.5 G2: −0.4 G1 vs. G2: p<0.001 CGI-Severity G1: −1.2 G2: −0.4 CGI-I – Very much improved or much improved G1: 31 (67) G2: 8 (16) CGI-I – Minimally improved G1: 7 (15) G2: 10 (20) CGI-I – No change G1: 6 (13) G2: 22 (45) CGI-I – Minimally worse G1: 2 (4) G2: 5 (10) CGI-I – Much or very much worse G1: 0 (0) G2: 4 (8)
Marcus 2011^15^ RCT G1: De Novo Subjects (2–15 mg/kg), 84/55 G2: Prior Placebo (2–15 mg/kg), 69/37 G3: Prior Aripiprazole (2–15 mg/kg), 169/107 52 weeks Moderate ROB | CGI-Severity G1: 4.8 ± 1 G2: 4.2 ± 1 G3: 3.9 ± 1.1 ABC-Irritability G1: 23.2 ± 8.9 G2: 21.5 ± 9.8 G3: 15 ± 9.2 ABC-Lethargy/Social Withdrawal G1: 14.6 ± 8.6 G2: 11.3 ± 9.2 G3: 10.4 ± 8.9 ABC-Stereotypic Behavior G1: 8.1 ± 5.2 G2: 9.1 ± 5.6 G3: 6.4 ± 5.5 ABC-Hyperactivity G1: 28.4 ± 10.9 G2: 25.8 ± 13.2 G3: 18.4 ± 12 ABC-Inappropriate Speech G1: 5.8 ± 3.2 G2: 5.7 ± 4.2 G3: 4.2 ± 3.6 | CGI-Severity G1: −1 ± 0.8 G2: −0.6 ± 1.2 G3: −0.1 ± 1 ABC-Irritability G1: −8 ± 10.1 G2: −6.1 ± 1.9 G3: 0.7 ± 10.2 ABC-Lethargy/Social Withdrawal G1: −6.4 ± 7.9 G2: −4.1 ± 7.2 G3: −2.3 ± 6.4 ABC-Stereotypic Behavior G1: −2.7 ± 3.1 G2: −1.9 ± 4.1 G3: −0.5 ± 4.4 ABC-Hyperactivity G1: −12.3 ± 8.5 G2: −9.1 ± 11.5 G3: 0.6 ± 10.3 ABC-Inappropriate Speech G1: −2 ± 2.5 G2: −1.8 ± 3 G3: −0.3 ± 2.4
Marcus 2011^16^ RCT G1: Aripiprazole (2–15 mg/kg; flexibly dosed study), 46/46 G2: Aripiprazole (5 mg/kg), 52/52 G3: Aripiprazole (10 mg/kg), 59/59 G4: Aripiprazole (15 mg/kg), 53/53 G5: Placebo (flexibly dosed study) 49/49 G6: Placebo (fixed-dose study) 49/49 8 weeks/EOT Moderate ROB | ABC-Irritability G1: 29.6 ± 1 G2: 28.3 ± 1 G3: 27.6 ± 0.9 G4: 28.3 ± 1 G5: 30.8 ± 1 G6: 26.9 ± 1 ABC-Social Withdrawal/Lethargy G1: 19.9 ± 1.6 G2: 17.7 ± 1.4 G3: 16.8 ± 1.3 G4: 18.9 ± 1.4 G5: 18.1 ± 1.6 G6: 18 ± 1.5 ABC-Stereotypic Behavior G1: 11.9 ± 0.9 G2: 11.4 ± 0.8 G3: 11.6 ± 0.8 G4: 10.7 ± 0.9 G5: 10.7 ± 0.8 G6: 10.7 ± 0.8 ABC-Hyperactivity G1: 34.1 ± 1.4 G2: 33.1 ± 1.4 G3: 33.7 ± 1.3 G4: 32.2 ± 1.4 G5: 34.7 ± 1.4 G6: 31 1. ± 4 ABC-Inappropriate Speech G1: 7 ± 0.6 G2: 5.8 ± 0.6 G3: 6.8 ± 0.5 G4: 6.3 ± 0.5 G5: 7 ± 0.6 G6: 5.9 ± 0.6 | Change scores ABC-Irritability G1: −12.9 ± 1.4 G2: −12.4 ± 1.4 G3: −13.2 ± 1.3 G4: −14.4 ± 1 G5: −5 ± 1.4 G6: −8.4 ± 1.4 G1 vs. G6, p<0.05 G2 vs. G6, p<0.05 G3 vs. G6, p<0.05 G4 vs. G6, p<0.05 ABC-Social Withdrawal/Lethargy G1: −7.9 ± 1.2 G2: −5.8 ± 1.2 G3: −4.9 ± 1.1 G4: −7.9 ± 1.1 G5: −62 ± 1.1 G6: −5.2 ± 1.2 G5 vs. G6, p=ns ABC-Stereotypic Behavior G1: −4.8 ± 0.6 G2: −4.5 ± 0.7 G3: −4.2 ± 0.6 G4: −4.5 ± 0.7 G5: −2 ± 0.6 G6: −1.8 ± 0.7 G1 vs. G6, p<0.05 G2 vs. G6, p<0.05 G3 vs. G6, p<0.05 G4 vs. G6, p<0.05 ABC-Hyperactivity G1: 12.7 ± 1.5 G2: −14 ± 1.6 G3: −13.3 ± 1.5 G4: −16.3 ± 1.6 G5: −2.8 ± 1.5 G6: −7.7 ± 1.7 G1 vs. G6, p<0.05 G2 vs. G6, p<0.05 G3 vs. G6, p<0.05 G4 vs. G6, p<0.05 ABC-Inappropriate Speech G1: −2.5 ± 0.4 G2: −2 ± 0.5 G3: −1.8 ± 0.4 G4: −2.3 ± 0.4 G5: −0.4 ± 0.4 G6: −1.1 ± 5 G4 vs. G6: p<0.05
Findling 2014^48^ RCT G1: Aripiprazole (2–15 mg/day), 41/22 G2: Placebo (NA), 44/19 16 weeks/EOT Low ROB | ABC-I – adjusted mean score NR CGI - improvement scale NR | Change scores ABC- I G1: 5.2 G2: 9.6 G1 vs. G2: p=ns ABC- Hyperactivity G1: 5.0 G2: 10.3 G1 vs. G2: p=0.041 ABC- Stereotypy G1: 0.8 G2: 2.8 G1 vs. G2: p=0.018 ABC- Inappropriate speech G1: 0.6 G2: 2.1 G1 vs. G2: p=0.013 ABC- Social withdrawal G1: 0 G2: 1.5 G1 vs. G2: p=ns CGI- I G1: 4.2 G2: 4.8 G1 vs. G2: p=ns

ABC = Aberrant Behavior Checklist; CGI-I = Clinical Global Impression Scale Improvement, EOT = end of treatment; G = group; kg = kilograms; mg = milligrams; NR = not reported; NS = not significant; RCT = randomized controlled trial; ROB = risk of bias; SD = standard deviation

Table 9 Key outcomes in studies comparing risperidone and aripiprazole

Author, Year, Study Design Groups (Dose), N Enrollment/N Final Treatment Duration/Follow-Up Time Point Post-Treatment Risk Of Bias | Baseline Scores, Mean ±SD | Post-Treatment Scores, Mean ± SD
Lamberti 2016^50^ RCT G1: Aripirazole (up to 15 mg/day), 22/19 G2: Risperidone (up to 3 mg/day), 22/18 24 weeks/EOT Low ROB | CGI – Severity G1: 5.4 ± 0.5 G2: 5.5 ± 0.6 CGAS – Total Score G1: 38 ± 8.3 G2: 31.42 ± 12.4 ADHD Rating Scale – Total Score G1: 39.4 ± 2.8 G2: 37.4 ± 3.9 CPRS – Hyperactivity G1: 5.7 ± 0.7 G2: 5.4 ± 0.7 CPRS – Inattention G1: 5.4 ± 0.8 G2: 4.9 ± 0.9 | CGI – Severity G1: 5.4 ± 0.5 G2: 5.5 ± 0.6 CGAS – Total Score G1: 38 ± 8.3 G2: 31.42 ± 12.4 ADHD Rating Scale – Total Score G1: 39.4 ± 2.8 G2: 37.4 ± 3.9 CPRS – Hyperactivity G1: 5.7 ± 0.7 G2: 5.4 ± 0.7 CPRS – Inattention G1: 5.4 ± 0.8 G2: 4.9 ± 0.9
Ghanizadeh 2014^49^ RCT G1: Aripiprazole (1.25–10 mg/day), 29/29 G2: Risperidone (0.25–3 mg/day), 30/30 2 months/EOT Low ROB | ABC-Irritability G1: 26.2 ± 4.1 G2: 21.5 ± 7.4 ABC-Hyperactivity G1: 37.1 ± 7 G2: 36 ± 6.2 ABC-Lethargy G1: 27.5 ± 8.4 G2: 25.3 ± 8.9 ABC-Stereotypy G1: 13.6 ± 5.7 G2: 13.2 ± 4.2 ABC-Speech G1: 8.6 ± 3.1 G2: 8.9 ± 3.6 | EOT ABC-Irritability G1: 14.6 ± 5.5 G2: 12.5 ± 5.4 G1 vs. G2: p=ns ABC-Hyperactivity G1: 21.1 ± 9 G2: 19.1 ± 6.1 G1 vs. G2: p=ns ABC-Lethargy G1: 17.3 ± 7.4 G2: 16.1 ± 6.9 G1 vs. G2: p=ns ABC-Stereotypy G1: 8.2 ± 5 G2: 7.4 ± 3.9 G1 vs. G2: p=ns ABC-Speech G1: 4.9 ± 2.3 G2: 5.7 ± 3.1 G1 vs. G2: p=ns CGI-Improvement, n Much improved G1: 9 G2: 5 Minimally improved G1: 7 G2: 12 No change G1: 5 G2: 8 Minimally worse G1: 3 G2: 2 G1 vs. G2: p=ns

ABC = Aberrant Behavior Checklist; CGI = Clinical Global Impression Scale; EOT = end of treatment; ES = effect size; G = group; mg = milligrams; N = number; NS = not significant; RCT = randomized controlled trial; ROB = risk of bias; SD = standard deviation

Table 10 Harms/adverse events reported by study phase in RUPP risperidone studies

Treatment Duration Adverse Event | Risperidone: 8 weeks^34^ (n=49) N (%) | Risperidone: 6 months^36^ (n=95) N (%) | Risperidone: 21.4 months (mean)^28^ (n=84) N (%) | Placebo: 8 weeks^34^ (n=51) N (%)
Accidental injury | NR | 2 (3.2) | NR | NR
Agitation/nervousness/restlessness | 3 (6) | 1 (1.6) | NR | 3 (6)
Anxiety | 12 (24) | 3 (4.8) | 7 (12.3) | 10 (20)
Appetite change | NR | NR | 4 (7.1)
Appetite increase | 36 (73) | 5 (7.9) | 24 (42.1) | 15 (29)
Appetite decrease | 3 (6) | NR | NR | 5 (10)
Depression/sadness | NR | 1 (1.6) | NR | NR
Dizziness | 8 (16) | NR | NR | 2 (4)
Drooling/increased saliva | 13 (27) | 2 (3.2) | 10 (17.5) | 3 (6)
Dry mouth | 9 (18) | NR | 6 (10.6) | 5 (10)
EPS/impaired movement | 18 (36) | 3 (4.8) | NR | 5 (10)
Gastrointestinal symptoms | 48 (98) | 7 (11.1) | 25 (44.2) | 43 (86)
Headache | 9 (18) | 2 (3.2) | NR | 6 (12)
Heart rate changes | 6 (12) | NR | NR | 1 (2)
Infection/fever/cold/congestion symptoms | 35 (71) | 18 (28.6) | 7 (12.5) | 23 (45)
Insomnia | 7 (14) | 3 (4.8) | NR | 15 (29)
Skin changes | 11 (22) | 3 (4.8) | 3 (5.4) | 7 (14)
Sleep changes | 11 (22) | NR | 6 (10.5) | 9 (18)
Fatigue | 23 (47) | 1 (1.1) | NR | 6 (12)
Drowsiness | 16 (32.6) | 2 (4.1) | 13 (15.5) | NR
Thirst | 6 (12) | NR | NR | 5 (10)
Urinary changes | 15 (31) | 3 (4.8) | 11 (19.6) | 15 (29)

EPS = Extrapyramidal Symptoms; N = number; NR = Not Reported; RUPP = Research Units on Pediatric Psychopharmacology

##### Studies of Risperidone

The four RCTs comparing risperidone and placebo included one study (reported in multiple publications) conducted by RUPP investigators (low risk of bias).^28–39, 112, 113^ In the initial 8-week trial including 101 children,^34^ baseline ratings of irritability were similar across risperidone and placebo arms. The risperidone arm had significantly greater decreases (improvement) in ABC-Irritability scores compared with the placebo arm (improvements of 15.1 vs. 3.6 points, p<0.001). Clinician ratings of outcomes considered by parents to be chief concerns paralleled these findings of significant improvement in challenging behavior in the risperidone group.^35^ In other sub-analyses of participants in the original 8-week trial, ABC-Social Withdrawal scores were significantly improved in the treatment group compared with placebo (mean difference of 3.82, p=0.05, effect size: 0.42) as were scores on the Children’s Yale-Brown Obsessive Compulsive Scale (CYBOCS) (p=0.005, effect size: 0.74), but scores on cognitive measures in a subset of 38 participants who were able to complete the assessments typically did not differ between groups, though no decline in cognitive skills was associated with treatment.^30, 38, 39^

In another series of followup papers from this original RCT, investigators randomized responders to risperidone from the original trial and children who originally received placebo and were considered placebo nonresponders but had subsequent positive response to risperidone to either risperidone or risperidone with gradual placebo replacement for 16 weeks.^31, 36^ More children in the gradual replacement arm (n=10, 62.5%) compared with risperidone (n=2, 12.5%, p=0.01) experienced relapse (25% increase in ABC-Irritability score and CGI-Improvement rating of much or very much worse compared with baseline). In followup analyses of these participants plus children from the initial 101 in the 8-week trial, children receiving risperidone for up to 16 weeks had significant improvements in parent-rated measures of affect, repetitive and restricted behaviors, and sensory responses compared with children receiving placebo, but measures of social relatedness or language did not differ between groups.^32^ In a report of 48 children participating in the 16-week extension and receiving risperidone, scores on Vineland Adaptive Behavior Scales (VABS) measures of communication and daily living skills improved significantly over the treatment period; however, this analysis lacked a control arm.^37^

In an extension of these analyses, investigators followed 84 of the initial 101 children in the 8-week trial (38 also participated in the extension trials).^28^ These 84 children received risperidone for some portion of the mean 21-month uncontrolled followup; children could have received another antipsychotic or other medication, but 96 percent received risperidone over the followup period, and 68 percent were taking an antipsychotic in the month prior to followup. CGI-Severity scores improved significantly from baseline, regardless of treatment in the original trial (effect size: −0.75) with risperidone. ABC-Irritability similarly improved significantly from baseline (effect size −1.01) as did the ABC-Social Withdrawal (effect size: −0.85), ABC-Stereotypy (effect size: −0.82), ABC-Hyperactivity (effect size: −1.07), and ABC-Inappropriate Speech (−0.41) scales. Scores on the CYBOCS also improved significantly from baseline (effect size: −0.79), while scores on the VABS typically improved, but not significantly. IQ did not change significantly with risperidone.

Finally, in post-hoc analyses reporting data from the original RUPP trial^34^ and an RUPP trial of risperidone compared with risperidone plus parent training^126^ (reported in detail in our 2011 review), effect sizes on the ABC-Social withdrawal subscale were 0.65 in the risperidone only group and 0.65 in the combination group;^39^ scores were significantly better than those of the placebo arm in the original 8-week trial or risperidone vs. placebo.^34^ In another subanalysis,^38^ effect sizes on the CYBOCS were 0.88 in the risperidone only group and 0.86 in the combination group, both significantly improved compared with the placebo arm in the original RUPP risperidone trial.

In another RCT (low risk of bias) comparing a low dose risperidone group, a high dose risperidone group, and a placebo group (total n=96), baseline scores for ABC-Irritability and the CGI scales were similar across all groups.^51, 52^ The high dose risperidone arm had the greatest improvement in ABC-Irritability scores, followed by the low-dose group and placebo. The difference between high dose risperidone and placebo alone was statistically significant (p<0.001), but differences between low dose and placebo were not. The study reported similar improvements in CGI, with the greatest decrease in CGI scores for high dose risperidone and statistically significant differences between only the high dose group and placebo (p<0.001). In a 6-month open label extension of risperidone including 79 (56 completers) of the 96 children originally enrolled in the RCT, children received either fixed dose or flexibly dose risperidone with a median dose of 0.875mg/day in the open-label phase. All groups improved from baseline on the ABC-Irritability scale, with no significant differences between groups. Other measures taken at the end of the study included ABC-Hyperactivity, ABC-Stereotypic Behavior, ABC-Inappropriate Speech, ABC-Social Withdrawal, CYBOCS, CGI-Severity and CGI-Improvement, all of which showed improvement from baseline with no significant group differences.

One moderate risk of bias RCT reported in the 2011 review reported statistically significant improvements on the ABC-Irritability, Stereotypy, and Hyperactivity subscales in children receiving risperidone compared with the placebo group.^112, 113^ The final RCT (moderate risk of bias) assessed outcomes after 6 months of risperidone treatment using a variety of general rating scales but provided quantitative data on only some of these scales.^109^ The primary outcome measures were parent ratings on the Childhood Autism Rating Scale (CARS) and clinician ratings on the Children’s Global Assessment Scale (CGAS). The study only reported CARS median ratings for those participants with at least a 20 percent response; more children receiving risperidone achieved this goal compared with placebo (12 vs. 0, p<0.001). Average ratings on the CGAS were similar in the risperidone (29.8) and placebo (32.7) arms, with more improvement in the risperidone vs. placebo arms (p=0.04). Parent-rated scores did not differ between groups.

In one discontinuation study, investigators randomized children who had responded to risperidone in an initial 24-week trial to discontinuation (taper for three weeks and 5 weeks off of risperidone) or continuation for eight weeks.^102^ For the primary outcome measure of relapse, 8 of 12 patients relapsed in the placebo group and 3 of 12 patients relapsed in the risperidone group (p=0.49). ABC-Irritably scores increased by 60 percent in the placebo group 14 percent in the risperidone group (p = 0.43). Differences in other ABC scales (Social Withdrawal, Stereotypy, Hyperactivity and Inappropriate Speech) were not statistically significant. Table 7 outlines key outcomes.

##### Studies of Aripiprazole

Two 8-week RCTs (low risk of bias) of aripiprazole compared with placebo were reported in our 2011 review.^20, 21^ In these two studies, baseline ratings of irritability were similar across aripiprazole and placebo arms (Table 8). Decreases in ABC-Irritability were significantly greater for the aripiprazole arms in both studies, with improvements of 12.4 to14.4, in comparison with the placebo arms, with improvements of 5.0 to 8.4. The trial with differing set doses of aripiprazole demonstrated increasing response with increasing dose.^20^ Overall, the results of the trial that used titration following clinical judgment were more pronounced.^21^ Decreases (improvements) in ABC-Hyperactivity and Stereotypy subscales were significantly greater in children receiving aripiprazole compared with placebo arms. Scores in the ABC-Inappropriate Speech subscale were also significantly improved in the treatment group vs. placebo in the flexibly dosed study but not in the fixed dose RCT. Both studies also used the CYBOCS scale to assess repetitive behavior, finding no baseline differences between the groups but a greater decrease in the aripiprazole compared with placebo arms (2.4 to 3.8 vs. 0.8 to 1.7). A number of other outcomes were measured in these two studies, but none outside of challenging behavior and repetitive behavior yielded statistically significant findings once corrected for multiple comparisons.

Post-hoc analyses of these RCTs analyzed changes in ABC scores^16^ and quality of life measures.^17^ The first post-hoc analysis^16^ analyzed the following changes in ABC subscales. Scores on the ABC-Irritability, Stereotypy, Hyperactivity, and Inappropriate Speech subscales were significantly improved in the aripiprazole arms compared with placebo (all p values <0.05), typically with greater decreases in the flexibly dosed group compared with the fixed dose group. Scores on the Social Withdrawal subscale did not differ significantly between treatment and placebo groups. Compared with placebo, the pooled aripiprazole groups had greater improvements in total health-related quality of life scores and emotional, social, and cognitive functioning scores measured using the Pediatric Quality of Life Inventory (all p values < 0.05).^17^ Children who received aripiprazole were also more likely to have clinically meaningful improvement on all these scales compared with those receiving placebo (odds ratios ranging from 1.2 to 2.2, p values <0.05).

Investigators extended these 8-week studies with an uncontrolled, 52-week open label analysis including 70 children who had received placebo in the original RCTs, 174 who had received aripiprazole, and 86 “de novo” subjects.^15^ Primary outcomes included the ABC-Irritability and CGI-Severity scales. ABC-Irritability mean scores at baseline were higher for the de novo (23.2±8.9) and prior placebo (21.5±9.8) groups compared with the prior aripiprazole group (15.0±9.2). Mean change from baseline in the de novo group was −8.0 ± −10.1 and in the prior placebo group was −6.1 ± 11.9. Improvements in scores in the de novo and prior aripiprazole groups occurred in first 8 weeks of the open label phase. The CGI decreased in the same manner, with greater reductions (improvements) in the de novo and prior placebo groups than in the prior aripiprazole group, in which improvements reported in the prior RCTs were maintained. Scores in the ABC-Hyperactivity subscale and CYBOCS followed similar patterns.

An additional low risk of bias RCT randomized 85 children who had shown a stable improvement (≥ 25% decrease in ABC-Irritability scores for 12 weeks) in an initial 13–26 week open label phase to continued, flexibly dosed aripiprazole or placebo until relapse (defined as ≥25% increase in ABC-Irritability score, CGI ratings of worse or much worse, loss-to-followup plus elevated scores, elevated scores plus initiation of other medication to treat symptoms, or discontinuation due to worsening symptoms) or 16 weeks.^48^ The difference between the two groups in time to relapse was not statistically significant (35% in the aripiprazole arm at 16 weeks vs. 52% in placebo, hazard ratio=0.57, 95% confidence interval [CI]: 0.28 to 1.12, number needed to treat=6). Mean change in the ABC-Irritability and Social Withdrawal scores or CGI-Improvement score from baseline to week 16 did not differ between groups (p≥0.05), but children in the placebo group had greater increases (i.e., worsening behavior) on the ABC-Hyperactivity and Inappropriate Speech subscales than did children in the treatment group (p values <0.05); pediatric quality of life measures also did not differ between groups.

##### Studies Comparing Risperidone and Aripiprazole

Three small studies comparing these agents reported no significant group differences in measures of challenging behavior or general improvement (Table 9). In one 24-week RCT (low risk of bias) comparing two groups of patients with ASD and attention deficit hyperactivity disorder (ADHD), both groups improved on measures of symptom severity including the ADHD Rating Scale and CGI (all p=NS) Of note, improvement with aripiprazole was evident in the first 12 weeks of treatment without additional improvements at 24 weeks, while scores on measures in children taking risperidone improved at 12 weeks and continued to improve over the 24 week period.^50^ Another 8-week RCT (low risk of bias) reported improvements in ABC-Irritability, Hyperactivity, Lethargy, Stereotypy, and Inappropriate speech scores in both risperidone and aripiprazole arms.^49^ Most patients were much or minimally improved on the CGI-Improvement scale, but differences between the groups on all of these scales were not statistically significant. Another retrospective cohort study (moderate risk of bias), which primarily reports weight change (see Harms section below), noted no significant group differences in mean CGI-Improvement scores (risperidone=3.2±1.2, aripiprazole=2.9±1.2, p=0.32) after treatment with risperidone (mean treatment duration=2.37±2.55 years) or aripiprazole (mean treatment duration=1.47±1.21 years).^122^ The study did not report CGI scores at baseline so the magnitude of change cannot be assessed.

##### Studies Comparing Risperidone and Other Agents

Haloperidol. In one small RCT (moderate risk of bias) comparing risperidone with haloperidol, both groups improved from baseline on the Ritvo-Freeman scale, ABC, and Turgay DSM-IV Pervasive Development Disorder scale, with significantly greater improvements in the risperidone group on the ABC and Turgay scales (p values <0.01).^101^ Appendix F outlines key data from this study.

Memantine. In one small RCT (moderate risk of bias) comparing risperidone with memantine, children in both groups improved significantly from baseline on all ABC subscales except stereotypy and on most CARS subscales (no improvements in either group in fear/nervousness, nonverbal communication, and intellectual response. Improvements in memantine arm on taste, smell, touch response and imitation), but differences between groups were not significant.^47^ CGI ratings were not significantly different between groups. Appendix F outlines key data from this study.

##### Harms of Antipsychotics

Risperidone. Table 10 outlines harms reported in study arms addressing risperidone. Among clinically important harms, appetite increase occurred in over 70 percent of children and extrapyramidal symptoms in 36 percent. Gastrointestinal symptoms (including constipation, diarrhea, and abdominal pain) occurred in nearly all children in the 8 week RCT, and more than 25 percent across phases experienced anxiety and hypersalivation. Across studies, six children withdrew due to adverse events.

Some studies reported comparative analyses of harms data: In the RUPP extension study urinary problems occurred in 19.6 percent of patients who took risperidone, and 0% of patients that did not (p=0.01). Excessive appetite occurred in 42.1 percent of patients who took risperidone and 20 percent of those who did not (p=ns). In another RCT comparing risperidone doses and placebo, the incidence of treatment-emergent adverse events was higher in the high dose group compared with the low dose group and placebo.^125, 127^ In combining high and low dose groups, the most common events included increased appetite (26%), sedation (15%), somnolence (11%) and weight increase (11%). Sedation, somnolence and increased appetite occurred with twice the frequency in the high dose group than in the low dose group.

In an analysis of prolactin changes in children participating in the RUPP trial, serum prolactin increased significantly from baseline in children taking risperidone at 8 weeks and 6 months, though concentrations were lower at 6 months than at weeks.^111^ Levels were higher in treated children compared with those in the placebo group. In the 20 treated children with measurements at 8 weeks, 6 months, and ~22 months, levels were significantly elevated at each time point compared with baseline, but levels at 22 months were significantly lower than those at 6 months (p=0.016). While these elevations represented 2 to 4 fold increases in prolactin, no children reported clinical complaints such as galactorrhea, gynecomastia, or menstrual changes. Another study reported no significant differences in weight change between risperidone and placebo groups (increase of 17% in the risperidone group and 9.3% in placebo).^109^

One analysis of side effects in a discontinuation study^102^ reported adverse events that occurred in at least 10 percent of patients taking risperidone, including increased appetite (mild-49%, moderate 8%), anxiety (mild 31%, moderate 7%), fatigue (mild 32%, moderate 3%), increased thirst (26%, enuresis (19%), insomnia, (17%), headache (13%), rhinitis (11%), stomachache (10%), nausea (10%) and drooling (10%). The authors did not report differences in groups during the discontinuation period.

Harms reported in other risperidone studies were similar (Table 11).

Table 11 Harms/adverse effects in other studies of risperidone

Harm/Adverse Event^a^ | N Studies Reporting Harm (# Participants With Harm/Total Participants) | Reported Rates Across Studies
Risperidone, 1–1.17mg/day
Appetite increase^49, 112, 113^ | 2 (21/70) | 22.5%–40%
Insomnia^112, 113^ | 1 (6/40) | 15%
Challenging behavior^112, 113^ | 1 (5/40) | 12.5%
Headache^112, 113^ | 1 (5/40) | 12.5%
Somnolence^49, 109, 112, 113^ | 3 (46/89) | 10%–72.5%
Drooling/increased saliva^49, 112, 113^ | 2 (16/70) | 10%–40%
Infection/fever/cold/congestion symptoms^112, 113^ | 1 (44/40) | 10%–37.5%
Appetite decrease^49, 112, 113^ | 2 (8/70) | 10%–13.3%
Gastrointestinal symptoms^49, 112, 113^ | 2 (25/70) | 3.3%–20%
EPS/impaired movement^49, 109, 112, 113^ | 3 (24/89) | 3.3%–16%
Heart rate changes^49, 112, 113^ | 2 (6/70) | 3.3%–12.5%
Agitation/nervousness/restlessness^49^ | 1 (3/30) | 10%
Dizziness^49^ | 1 (3/30) | 10%
Weight gain^112, 113^ | 1 (4/40) | 10%
Urinary changes^49^ | 1 (2/30) | 6.7%
Risperidone, 1.25–1.75mg/day
Somnolence^51, 52^ | 1 (20/31) | 64.5%
Infection/fever/cold/congestion symptoms^51, 52^ | 1 (7/25) | 28%
EPS/impaired movement^51, 52^ | 1 (7/31) | 22.6%
Gastrointestinal symptoms^51, 52^ | 1 (4/25) | 16%
Pain^51, 52^ | 1 (2/25) | 8%
Risperidone, 0.125–0.175mg/day
Infection/fever/cold/congestion symptoms^51, 52^ | 1 (8/24) | 33.3%
Gastrointestinal symptoms^51, 52^ | 1 (4/24) | 16.7%
Somnolence^51, 52^ | 1 (3/30) | 10%
Appetite increase^51, 52^ | 1 (2/24) | 8%
EPS/impaired movement^51, 52^ | 1 (2/24) | 8%
Insomnia^51, 52^ | 1 (2/24) | 8%
Risperidone (0.01 – 0.08 mg/kg/day)
Gastrointestinal symptoms^101^ | 1 (3/13) | 23.1%
Urinary changes^101^ | 1 (3/13) | 23.1%
Infection/fever/cold/congestion symptoms^101^ | 1 (7/13) | 53.8%
Risperidone (0.5 – 3.5 mg/kg/day)
Appetite increase (mild)^102^ | 1 (13/26) | 49%
Appetite increase (moderate)^102^ | 1 (3/12) | 8%
Anxiety (mild)^102^ | 1 (8/12) | 7%–1%
Anxiety (moderate)^102^ | 1 (1/12) | 7%
Fatigue (mild)^102^ | 1 (8/12) | 32%
Fatigue (moderate)^102^ | 1 (1/12) | 3%
Thirst^102^ | 1 (7/12) | 26%
Urinary changes^102^ | 1 (5/12) | 19%
Insomnia^102^ | 1 (4/12) | 17%
Headache^102^ | 1 (3/12) | 13%
Infection/fever/cold/congestion symptoms^102^ | 1 (3/12) | 11%
Gastrointestinal symptoms^102^ | 1 (6/12) | 10%
Drooling/increased saliva^102^ | 1 (3/12) | 10%
Risperidone (up to 3 mg/kg/day)
Appetite increase^47, 50^ | 2 (19/34) | 50%–53%
Abnormal behavior^47^ | 1 (3/15) | 20%
Agitation/nervousness/restlessness^50^ | 1 (1/19) | 4%
Anxiety^50^ | 1 (1/19) | 4%
Drooling/increased saliva^47, 50^ | 2 (3/34) | 6.7%–9%
Dry mouth^50^ | 1 (3/19) | 13%
Enuresis^47, 50^ | 2 (6/34) | 13.3%–18%
EPS/impaired movement^50^ | 1 (1/19) | 4%
Fatigue^47^ | 1 (1/15) | 6.7%
Gastrointestinal symptoms^50^ | 1 (1/19) | 4%
Infection/fever/cold/congestion symptoms^47^ | 1 (5/15) | 6.7%–26.7%
Somnolence^47, 50^ | 2 (11/34) | 27%–33.3%
Weight gain^50^ | 1 (8/19) | 42%
Placebo
Agitation/nervousness/restlessness^51, 52^ | 1 (2/30) | 7%
Appetite increase^51, 52, 112, 113^ | 2 (11/69) | 15.9%
Challenging behavior^51, 52^ | 1 (3/35) | 9%
EPS/impaired movement^51, 52, 112, 113^ | 2 (4/58) | 6.9%
Gastrointestinal^48, 51, 52, 112, 113^ | 3 (20/117) | 17.1%
Headache^51, 52, 112, 113^ | 2 (9/74) | 12.2%
Infection/fever/cold/congestion symptoms^48, 51, 52, 112, 113^ | 3 (35/112) | 31.3%
Insomnia^51, 52, 112, 113^ | 2 (9/74) | 12.2%
Somnolence^51, 52, 112, 113^ | 2 (15/74) | 20.3%
Urinary changes^51, 52^ | 1 (2/30) | 7%

a Harms reported by more than one participant;

EPS = Extrapyramidal Symptoms; kg = kilograms; mg = milligrams; N = number

Aripiprazole. Table 12 outlines harms reported in study arms addressing aripiprazole. Harms reported across studies included weight gain, appetite changes, lethargy, and extrapyramidal symptoms. Across studies 34 children withdrew due to adverse events. Some studies reported comparative analyses of harms data: in an analysis of harms reported in two 8-week trials^20, 21^ of aripiprazole vs. placebo, the percentage of patients who discontinued due to at least adverse event with aripiprazole was 10.4 percent compared with 6.9 percent in the placebo groups.^19^ The most common adverse events reported in the aripiprazole groups compared with placebo were: sedation (10.4% vs. 4.0%), fatigue (16.5% vs. 2.0%), vomiting (13.7% vs 6.9%), increased appetite 12.7% vs. 6.9%), somnolence (10.4% vs. 4.0%), and tremor (9.9% vs. 0.0%). Younger children (6–12 years) had a higher group rate of salivary hypersecretion in the aripiprazole group (6.6% vs 0% in the placebo group), but older children (13–17 years) did not. The majority of adverse events had a peak incidence of onset at week 1 or 2, except for nasopharyngitis and tremor, which had a peak incidence at week 3, extrapyramidal disorder and aggression at week 4, drooling at week 5, diarrhea at weeks 2 and 5, enuresis and upper respiratory tract infection at week 6 and cough at week 7. Investigators rated most adverse events as mild or moderate. Most of the adverse events rated as severe were in the younger (6–12 years) subgroup, with one event of severe fatigue in the 13–17 age group. Fatigue was the only adverse event that showed a statistically significant dose-response relationship, with 3.8 percent reporting fatigue at 5mg/d, 22 percent at 10mg/d and 18.5 percent at 15mg/d. The adjusted mean change (last observation carried forward) in body weight was higher in the aripiprazole group (1.6 kg) than the placebo group (0.4 kg) (p<0.001). The median change in BMI (0.7 vs. 0.2 kg/m2) was also higher in the aripiprazole group than the placebo group. Extrapyramidal-related adverse events were also more frequent in the aripiprazole group (20.8% vs. 9.9%). The most common extrapyramidal-related adverse events were tremor (9.9% vs 0% in placebo) and extrapyramidal disorder (6.1% vs 0% in placebo).

Table 12 Harms/adverse events reported by study phase in aripiprazole “family” studies

Treatment Duration Adverse Event | Aripiprazole: Fixed Dose+Flexible Dose, 8 weeks^19^ (n=212^a^) N (%) | Aripiprazole: 52 week open label extension^18^ (n=330) N (%) | Placebo: 8 weeks^19^ (n=101) N (%)
Agitation/nervousness/restlessness | NR | 21 (6.4) | NR
Anxiety | NR | 13 (3.9) | NR
Appetite increase | 27 (12.7) | 43 (13.0) | 7 (6.9)
Appetite decrease | 14 (6.6) | 15 (4.5) | 2 (2.0)
Challenging behavior | 6 (2.8) | 44 (13.3) | 7 (6.9)
Drooling/increased saliva | 31 (14.7) | 22 (6.7) | 1 (1.0)
Epistaxis | NR | 21 (6.4) | NR
EPS/impaired movement | 34 (16.0) | 16 (4.8) | 0
Gastrointestinal symptoms | 56 (26.4) | 132 (40.0) | 20 (19.8)
Headache | 16 (7.5) | 32 (9.7) | 10 (9.9)
Infection/fever/cold/congestion symptoms | 56 (26.4) | 220 (70.8) | 16 (16.0)
Insomnia | 11 (5.2) | 33 (10.0) | 11 (10.9)
Lethargy | 10 (4.7) | 10 (3.0) | 0
Menstrual | NR | 1 (2.3) | NR
Skin changes | NR | 15 (4.5) | NR
Somnolence | 101 (47.7) | 63 (19.1) | 10 (10.0)
Urinary changes | 7 (3.3) | 15 (4.5) | 5 (5.0)
Weight gain | NR | 76 (23.0) | NR

a Study reported only events occurring in at least 5% of participants.

EPS = extrapyramidal symptoms; N = number; NR = not reported

In the 52-week open label extension of these trials, 286 of 330 patients (86.7%) reported adverse events.^18^ Discontinuations were significant in the three groups: 36 percent of de novo patients discontinued, 47.1 percent of prior placebo patients discontinued, and 38.5 percent of prior aripiprazole patients discontinued. Common reasons for discontinuation were adverse events, withdrawal of consent, lost to follow up and lack of efficacy. The most common adverse events reported from the three groups combined were weight increased (23%), vomiting (18.8%), nasopharyngitis (13.3%), increased appetite (13.0%), pyrexia (11.8%), upper respiratory tract infection (11.5%), insomnia (10.0%), headache (9.7%), cough (9.4%), diarrhea (9.1%), aggression (8.8%), sedation (8.2%) and fatigue (7.0%). Drooling, agitation, epistaxis, ear infection, nasal congestion, sinusitis, and constipation were also reported in >5% of patients.

In another RCT, 56.4 percent of children in the aripiprazole group reported a treatment-emergent adverse event compared with 32.6 percent of the placebo group. Adverse events reported by at least 5 percent of participants and at least twice the rate of placebo included upper respiratory tract infections (10.3% for aripiprazole vs. 2.3% for placebo), constipation (5.1% for aripiprazole vs. 0% for placebo), and movement disorder (5.1% for aripiprazole vs. 0% for placebo, p=NR). Weight change was 0.15 standard deviations greater in the aripiprazole group compared with placebo (mean gain of 2.2kg vs. 0.6kg, p=0.001). Fasting metabolic measurements were not different between groups, but the mean change in prolactin showed a difference of −4.8 (95% CI: −6.8 to −2.9; −0.2ng/ml for aripiprazole and 4.6ng/ml for placebo).^48^

Harms reported in other studies of aripiprazole were similar (Table 13).

Table 13 Harms/adverse effects in other studies of aripiprazole

Harm/Adverse Event^a^ | N Studies Reporting Harm (# Participants With Harm/Total Participants) | Reported Rates Across Studies
Appetite decrease^49^ | 1 (6/29) | 20.7%
EPS/impaired movement^48, 49^ | 2 (14/68) | 20.6%
Weight gain^50^ | 1 (4/18) | 18%
Skin changes^49^ | 1 (4/29) | 13.8%
Infection/fever/cold/congestion symptoms^48^ | 1 (4/39) | 10.3%
Enuresis^50^ | 1 (2/18) | 9%
Somnolence^49, 50^ | 2 (15/47) | 18%–37.9%
Appetite increase^49, 50^ | 2 (15/47) | 22%–34.5%
Drooling/increased saliva^49, 50^ | 2 (10/47) | 4%–31%
Gastrointestinal symptoms^48–50^ | 3 (16/86) | 9%–20.6%
Agitation/nervousness/restlessness^49, 50^ | 2 (4/47) | 4%–10.3%
Dry mouth^49, 50^ | 2 (4/47) | 6.9%–9%
Heart rate changes^49^ | 1 (2/29) | 6.9%
Anxiety^50^ | 1 (1/18) | 4%
Dizziness^50^ | 1 (1/18) | 4%
Insomnia^50^ | 1 (1/18) | 4%

a Harms reported by more than one participant.

EPS = extrapyramidal symptoms; N = number

Risperidone Versus Aripiprazole. In one RCT the three most common side effects in both groups were increased appetite, weight gain and drowsiness.^50^ Differences in changes in height, weight gain, BMI and blood glucose between the two groups were not statistically significant, while prolactin increased in the risperidone arm compared with aripiprazole (mean increase from 167.5± 80 to 464± 190 in the risperidone group, mean decrease from 158.2± 70.2 to 127.5± 75.1 in the aripiprazole group, p<0.001). One retrospective cohort study compared these agents in 142 children, all of whom were relatively overweight at baseline (BMI Z scores of 0.67±1.44 in children receiving risperidone and 0.64±1.94 in those receiving aripiprazole, p=ns).^122^ Children taking aripiprazole were older than those taking risperidone at baseline (9.74±3.46 years vs. 8.41±3.59, p=0.03), and children taking risperidone had a longer mean treatment duration (2.37±2.55 vs. 1.47±1.21 years, p=0.01). Other demographic characteristics and use of concomitant medications did not differ significantly between groups. Both groups gained weight over time (significant increases in BMI and BMI Z-scores in each group), with no significant group differences in BMI change per year of treatment (2.36±3.80 in risperidone group vs. 2.05±5.02 for aripiprazole, p=0.68) or BMI Z-score change per year of treatment (0.53±1.21 for risperidone vs. 0.56±2.21 for aripiprazole, p=0.91). Investigators note that the study was underpowered to detect differences in Z-scores. In another RCT, four children withdrew from the study because of adverse events.^49^

Risperidone Versus Haloperidol. Alanine amino transferase (ALT) was increased in the haloperidol group and decreased in the risperidone group (p=0.04) and prolactin increased more in the risperidone group vs. the haloperidol group (p=0.01). Both groups experienced weight gain (risperidone increase from 33.3kg ± 9.1 to 37.6 ± 9.8, haloperidol 42.1± 17.9 to 46.7 ± 18, p=NS), constipation, enuresis, and upper respiratory tract infections.

### Studies of Medications Used To Treat ADHD

#### Key Points

- Both RCTs addressing methylphenidate reported significant improvements in hyperactivity in children treated with medium to high doses compared with placebo. One RCT also noted significant treatment effects on inattention. Harms were frequent and included challenging behavior, anxiety, and appetite changes.
- Methylphenidate improved hyperactivity vs. placebo and was associated with clinically significant harms. Our confidence in these conclusions is low as studies were small and short term (low strength of evidence). Data were inadequate to assess effects on social communication and oppositional behavior (insufficient strength of evidence).
- Studies of atomoxetine compared with placebo reported promising findings related to improvements in hyperactivity in children with ASD and ADHD with clinically moderate adverse effects.
- We found positive effects of atomoxetine compared with placebo on hyperactivity in children with ASD and ADHD and moderate harms. Our confidence in these conclusions is low (low strength of evidence). Data were inadequate to assess effects on inattention as studies reported inconsistent findings (insufficient strength of evidence).
- One RCT of guanfacine reported significant improvements in hyperactivity in treated participants compared with the placebo group and no significant group differences in measures of cognitive skills. Harms included drowsiness and fatigue.
- Data were inadequate to assess effects of guanfacine given the small sample size and short-term assessment in one RCT (insufficient strength of evidence).

#### Overview of the Literature

We identified five RCTs (reported in multiple publications) addressing medications for ADHD.^24–27, 40–46^ Two RCTs addressed methylphenidate ^24–27, 45^ One study, conducted by the RUPP network, was included in our 2011 review.^24–27^ Two RCTs assessed atomoxetine.^40–44^ We describe effectiveness outcomes reported in another RCT comparing atomoxetine with and without parent training and placebo with and without parent training^54, 55^ in the section on Studies Addressing Combined Medical and Behavioral Treatments but report harms data from this study with other atomoxetine studies. Finally, one RCT evaluated guanfacine,^46^

Studies included a total of 265 children between the ages of 5 and 17. Four RCTs had low risk of bias, ^24–27, 41–45^ and one had moderate.^40^ Studies were conducted in the United States^24–27, 40, 45, 46^ Treatment duration ranged from 4 to 28 weeks, with one trial including a 4-week randomized phase and an 8-week open label continuation phase^24–27^ and another including 8 weeks of treatment followed by a 20-week open label phase.^41–44^

#### Detailed Analysis

Studies of methylphenidate, atomoxetine, and guanfacine reported improvements in hyperactivity and other challenging behaviors with treatment compared with placebo (Table 14). Side effects were associated with all agents, including aggressive behavior and appetite changes (methylphenidate); irritability and gastrointestinal symptoms (atomoxetine); and gastrointestinal symptoms and somnolence (guanfacine).

Table 14 Key outcomes in studies of ADHD medications

Author, Year, Study Design Groups (dose), N enrollment/N Final Treatment Duration Risk of Bias | Baseline Scores, Mean ±SD | Post-Treatment Scores, Mean ± SD
Methylphenidate
McCracken 2014^24–27^ RCT (crossover) Total N=66 G1: MPH - low dose (0.125 mg/kg), 66/45 G2: Methylphenidate - medium dose (0.250 mg/kg), 66/52 G3: MPH - high dose 0.500 mg/kg (), 66/33 G4: MPH - optimal dose (NR), 66/58 G5: Placebo (NA), 66/46 13 weeks/EOT Low ROB | Overall ratings: CGI severity sub-scale rating, n (%): Moderately ill: 20 (30.3) Markedly ill: 35 (52.0) Severely ill: 11 (16.7) ABC score, parent-rated, mean ± SD (range):^†^ Irritability: 16.9 ± 10.1 (0–41) Lethargy/social withdrawal: 12.1 ± 8.9 (0–33) Stereotypy: 7.6 ± 5.9 (0–21) Hyperactivity: 33.2 ± 8.7 (2–47) Inappropriate speech: 6.0 ± 4.1 (0–12) ABC score, teacher-rated, mean ± SD (range):^†^ Irritability: 16.1 ± 9.4 (0–43) Lethargy/social withdrawal: 15.5 ± 10.9 (0–42) Stereotypy: 7.6 ± 5.1 (0–19) Hyperactivity: 30.9 ± 7.9 (16–45) Inappropriate speech: 5.8 ± 3.6 (0–12) | ABC-hyperactivity subscale score, mean ± SD: Parent-rated: G1: 23.0 ± 11.29 G2: 20.6 ± 10.27 G3: 22.1 ± 9.67 G4: 17.2 ± 9.87 G5: 26.0 ± 9.90 G1 vs. G5: p = 0.03 (ES = 0.29) G2 vs. G5: p < 0.001 (ES = 0.54) G3 vs. G5: p = 0.003 (ES = 0.40) G4 vs.G5: p < 0.001 (ES = 0.89) Teacher-rated: G1: 22.9 ± 12.84 G2: 23.6 ± 12.53 G3: 20.3 ± 11.94 G4: 20.1 ± 12.40 G5: 26.0 ± 11.66 G1 vs. G5: p = 0.03 (ES = 0.25) G2 vs.G5: p = 0.008 (ES = 0.20) G3 vs.G5: p = 0.002 (ES = 0.48) G4 vs.G5: p < 0.001 (ES = 0.48)
Pearson 2013^45^ RCT (crossover) G1: MPH - low dose (0.125 mg/kg), 24/24 G2: MPH - medium dose (0.250 mg/kg), 24/24 G3: MPH - high dose (0.500 mg/kg), 24/24 G4: Placebo, 24/24 4 weeks/EOT Low ROB | ABC NR | EOT Parent Ratings ABC-Irritability G1: 10 ± 9.2 G2: 8.2 ± 8.1 G3: 7.2 ± 6.9 G4: 12.6 ± 10.4 ABC-Social Withdrawal/Lethargy G1: 7.3 ± 5.6 G2: 8.1 ± 5.9 G3: 8.5 ± 6.6 G4: 9.3 ± 8.1 ABC-Stereotypy G1: 4.3 ± 4.5 G2: 4 ± 3.8 G3: 3.5 ± 3.8 G4: 4.9 ± 5.4 ABC-Hyperactivity G1: 18.1 ± 10.5 G2: 14.5 ± 7.7 G3: 14.5 ± 9.2 G4: 24.1 ± 13 ABC-Inappropriate Speech G1: 4.3 ± 3.2 G2: 4 ± 3.1 G3: 3.9 ± 3.1 G4: 5.2 ± 3.1 CGI-Severity (clinician 1) G1: 4 ± 0.81 G2: 3.8 ± 0.82 G3: 3.8 ± 0.74 G4: 4.8 ± 0.61 CGI-Improvement (clinician 1) G1: 2.8 ± 1.3 G2: 2.4 ± 1.3 G3: 2.1 ± 1.2 G4: 4 ± 0.81 CGI-Severity (clinician 2) G1: 4 ± 0.72 G2: 4 ± 0.62 G3: 3.9 ± 0.74 G4: 4.7 ± 0.76 CGI-Improvement (clinician 2) G1: 2.8 ± 1.4 G2: 2.6 ± 1.3 G3: 2 ± 1 G4: 4.1 ± 0.95
Atomoxetine
Van der Meer 2013^41–44^ RCT G1: Atomoxetine (1.2mg/kg/day), 48/43 G2: Placebo (NA), 49/46 8 weeks/EOT Low ROB | ADHD Rating Scale – Total Score G1: 40.7 ± 7.5 G2: 38.6 ± 8.4 ADHD Rating Scale – Inattention G1: 20.7 ± 3.9 G2: 20.6 ± 4.6 ADHD Rating Scale – Hyperactivity/impulsivity G1: 20.0 ± 5.3 G2: 17.9 ± 6.1 CTRS-R:S – Oppositional G1: 4.1 ± 3.5 G2: 3.6 ± 3.5 CTRS-R:S – Hyperactivity G1: 8.8 ± 5.5 G2: 8.2 ± 5.1 CTRS-R:S – Cognitive/Attention G1: 6.8 ± 4.5 G2: 4.8 ± 3.7 CTRS-R:S – ADHD G1: 18.5 ± 9.3 G2: 18.1 ± 7.5 Go/No-Go Task – Proportion false alarms G1: 0.07 ± 0.1 G2: 0.06 ± 0.08 Missed Go Signals – Proportion misses G1: 0.02 ± 0.06 G2: 0.02 ± 0.05 Response Time G1: 532.7 ± 144.9 G2: 485 ± 120.7 Response Time Variability G1: 125.1 ± 64 G2: 120 ± 77.2 ABC – Irritability G1: 17.3 ± 9.1 G2: 16.2 ± 9.5 ABC – Lethargy/Social Withdrawal G1: 12.5 ± 8.4 G2: 12.5 ± 8 ABC – Stereotypic Behavior G1: 6.5 ± 5.1 G2: 4.1 ± 4.5 ABC – Hyperactivity G1: 28.4 ± 9.3 G2: 25.4 ± 11.5 ABC – Inappropriate Speech G1: 4.7 ± 3.2 G2: 4.6 ± 3.4 CSBQ – Total Score G1: 53.6 ± 14.8 G2: 53.1 ± 15.7 | EOT (8 wks) ADHD Rating Scale – Total Score G1: 31.2 (29.2–33.9) G2: 38.3 (36.0–40.5) G1 vs. G2: p<0.001 ADHD Rating Scale – Inattention G1: 17.0 (15.7–18.4) G2: 19.9 (18.7–21.1) G1 vs. G2: p=0.002 ADHD Rating Scale – Hyperactivity/impulsivity G1: 14.2 (12.8–15.7) G2: 18.4 (17.0–19.7) G1 vs. G2: p=0.001 CTRS-R:S – Oppositional G1: 3.2 (2.3 – 4) G2: 3.7 (2.9 – 4.6) G1 vs. G2: p=0.37 CTRS-R:S – Hyperactivity G1: 6.8 (5.5 – 8) G2: 8.8 (7.6 – 10) G1 vs. G2: p=0.024 CTRS-R:S – Cognitive/Attention G1: 5.1 (4.4 – 5.8) G2: 5.8 (5.1 – 6.5) G1 vs. G2: p=0.18 CTRS-R:S – ADHD G1: 15.1 (13 – 17.2) G2: 17.8 (15.7 – 19.8) G1 vs. G2: p=0.077 ABC – Irritability G1: 14.6 G2: 15.6 G1 vs. G2: p=0.452, d=0.2 ABC – Lethargy/Social Withdrawal G1: 11.4 G2: 11.7 G1 vs. G2: p=0.850, d=0.0 ABC – Stereotypic Behavior G1: 3.0 G2: 4.6 G1 vs. G2: p=0.014, d=0.5 ABC – Hyperactivity G1: 21.2 G2: 25.6 G1 vs. G2: p=0.010, d=0.6 ABC – Inappropriate Speech G1: 3.7 G2: 4.5 G1 vs. G2: p=0.045, d=0.4 CSBQ – Total Score G1: 46.2 G2: 50.1 G1 vs. G2: p=0.069, d=0.4 CGI – Very Much Improved G1: 0 (0) G2: 1 (2.2) CGI – Much Improved G1: 9 (20.9) G2: 3 (6.5) G1 vs. G2: p=ns CGI – Minimally Improved G1: 12 (27.9) G2: 6 (13) CGI – No Change G1: 16 (37.2) G2: 30 (65.2) CGI – Minimally Worse G1: 4 (9.3) G2: 3 (6.5) CGI – Much Worse G1: 2 (4.7) G2: 3 (6.5) CGI – Very Much Worse G1: 0 (0) G2: 0 (0)
Arnold 2006^40^ RCT G1: Atomoxetine (up to 1.4mg/kg/day), 16/16 G2: Placebo (1.2 mg/kg/day), 16/16 6 weeks/EOT (crossover) Moderate ROB | ABC – Hyperactivity G1: 24.69 ± 13.08 G2: 22.5 ± 12.87 ABC – Irritability G1: 16 ± 9.28 G2: 14.13 ± 9.89 ABC-Lethargy/social withdrawal G1: 8.69 ± 9.24 G2: 6.62 ± 8.36 ABC – Stereotypic behavior G1: 7.37 ± 6.20 G2: 6.19 ± 5.86 ABC – Inappropriate speech G1: 5.75 ± 3.38 G2: 5.43 ± 3.16 CGI-Severity G1 + G2: 4.69 ± 0.60 Repetitive behavior scales – Total score G1: 53.12 ± 22.2 G2: 49.06 ± 21.54 | Week 6 ABC – Hyperactivity G1: 19.31 ± 13.42 G2: 22.37 ± 12.89 G1 vs. G2: p=0.04; ES=0.9 ABC – Irritability G1: 13.06 ± 9.28 G2: 14.13 ± 9.89 G1 vs. G2: p=ns; ES=0.61 ABC-Lethargy/social withdrawal G1: 6.50 ± 8 G2: 7.43 ± 9.64 G1 vs. G2: p=0.01; ES=1.18 ABC – Stereotypic behavior G1: 4.69 ± 5.84 G2: 6.63 ± 5.8 G1 vs. G2: p=ns; ES=0.87 ABC – Inappropriate speech G1: 4.87 ± 2.85 G2: 5.43 ± 3.16 G1 vs. G2: p=ns; ES=0.52 CGI-Improvement (1 or 2) G1: 9 (56) G2: 4 (25) Repetitive behavior scales – Total score G1: 43.5 ± 23.94 G2: 45 ± 5.99 G1 vs. G2: p=ns; ES=0.09
Guanfacine
Scahill 2015^46^ RCT G1: Extended-Release Guanfacine (1–3 mg/day), 30/26 G2: Placebo (NA), 32/28 8 weeks/EOT Low ROB | ABC-Irritability G1: 20.30 ± 9.4 G2: 18.06 ± 9.77 ABC-Social withdrawal G1: 13.60 ± 9.43 G2: 12.06 ± 9.29 ABC-Stereotypy G1: 8.53 ± 5.69 G2: 9.31 ± 5.56 ABC-Hyperactivity G1: 34.40 ± 5.35 G2: 34.25 ± 6.97 ABC-Inappropriate speech G1: 6.33 ± 3.53 G2: 6.84 ± 3.38 | ABC-Irritability G1: 13.5 G2: 16.1 G1 vs. G2: p=ns ABC-Social withdrawal G1: 9.8 G2: 8.6 G1 vs. G2: p=ns ABC-Stereotypy G1: 3.6 G2: 5.9 G1 vs. G2: p=0.02 ABC-Hyperactivity G1: 19.3 G2: 29.7 G1 vs. G2: p<0.001 ABC-Inappropriate speech G1: 4.2 G2: 5.99 G1 vs. G2: p=0.004

ABC = Aberrant Behavior Checklist; ADHD = attention deficit hyperactivity disorder; CGI = Clinical Global Impressions Scale; CSBQ = Children’s Social Behavior Questionnaire; CTRS = Connor’s Teacher Rating Scales; EOT = end of treatment; ES = effect size; G = groups; kg = Kilograms; mg = milligrams; NA = not applicable; NS = not significant; RCT = randomized controlled trial; ROB = risk of bias; SD = standard deviation

Methylphenidate. The RUPP Autism Network’s double-blind cross-over trial of methylphenidate compared a one-day placebo followed by two days at each of three (low, medium, high) test doses of methylphenidate;^25–27^ doses ranged from 7.5 mg/day to 50.0 mg/day. Children tolerating methylphenidate (n=66) moved on to a 4-week, double-blind crossover phase. Children with a positive response in the double blind phase (n=34) completed an 8-week open-label continuation phase at their best dose. The primary outcome measure was hyperactivity as assessed by the ABC teacher-rated hyperactivity subscale; secondary measures included the ABC parent-rated hyperactivity subscale. Blinded clinicians also assessed participants using the Clinical Global Impression (CGI)-Irritability scale; investigators combined this subscale and the ABC parent and teacher rated hyperactivity subscales to assess response (Table 14).

In the double-blind crossover phase, all methylphenidate doses demonstrated effects that were statistically superior to placebo, and effect sizes favored the medium dose for parent ratings and high dose for teacher ratings. Parent-rated lethargy/social withdrawal significantly worsened during the high dose of methylphenidate compared with placebo. Parent-rated stereotypy and inappropriate speech scores improved significantly at the medium dose of methylphenidate compared with placebo. Hyperactivity/impulsivity also improved more with the medium and high methylphenidate doses than at the low dose. Significantly more joint attention behaviors occurred in the intervention group both at the best methylphenidate dose and at the low dose compared with placebo. Self-regulation, as assessed in a “competing demands” task, improved in low dose as well as in medium dose methylphenidate compared with placebo, and neutral affect significantly increased at the medium and high dose, which could be either beneficial, in the case of children with a labile mood, or damaging, in the case of children with flattened affect due to a medication side effect.^25–27^

In another 4-week RCT comparing extended release methylphenidate and placebo in children with ASD and significant ADHD symptoms with higher IQs (mean=85±16.8), children in the treatment group received extended release methylphenidate (low, medium, or high doses) in the morning and immediate release methylphenidate in the afternoon.^45^ Parent-rated measures of attention, ASD symptoms, hyperactivity and impulsivity improved significantly more at higher doses compared with lower doses and with placebo, and teachers reported significant improvements in hyperactivity, inattention and impulsivity at higher doses compared with lower doses and with placebo. Teachers (but not parents) also reported significant improvements in oppositional behavior with high dose methylphenidate compared with placebo. Neither teachers nor parents reported significant group differences in measures of emotional lability or social communication. Clinician-rated severity was significantly improved at all methylphenidate doses compared with placebo.

Atomoxetine. Two RCTs of atomoxetine reported significant treatment-related improvements compared with placebo that were maintained over 20 weeks of open label, uncontrolled treatment in one study; inattention was significantly improved in one study, and side effects were generally moderate (Table 16). In one low risk of bias RCT (reported in multiple publications), the initial study phase included participants with ASD and ADHD and compared atomoxetine with placebo.^41–44^ After 8 weeks of treatment, the atomoxetine group improved significantly more on the clinician-rated ADHD Rating Scale total score and on the inattention and hyperactivity/impulsivity subscales (p values ≤ 0.003). Nine of 48 treatment group participants and 4/49 placebo group were considered very much or much improved in the CGI-ADHD-I (p=ns). Scores on only the hyperactivity subscale of the Conners Teacher Rating Scale were significantly different between groups (difference in least square means: −2.0 [95% CI: −3.7 to −0.3], p=0.02). Children in the atomoxetine arm also had greater improvements on the ABC Hyperactivity, Inappropriate Speech, and Stereotypic Behavior (but not other subscales) than did children receiving placebo (p values <0.05, effect sizes of 0.4 to 0.6). Scores on the Children’s Social Behavior Questionnaire did not differ between groups. Response inhibition (as measured using a go-no go task) improved significantly in the atomoxetine group versus placebo but distractibility did not.^41^

Table 16 Harms/adverse effects in studies of atomoxetine

Harm/Adverse Event^a^ | N Studies Reporting Harm (# Participants With Harm/Total Participants) | Reported Rates Across Studies
Atomoxetine
Somnolence^40^ | 1 (12/16) | 75%
Skin changes^40^ | 1 (8/16) | 67%
EPS/impaired movement^40^ | 1 (7/16) | 43.8%
Constipation^54, 55^ | 1 (20/64) | 31%
Abdominal pain^54, 55^ | 1 (19/64) | 30%
Vomiting^54, 55^ | 1 (19/64) | 28%
Dry mouth^40^ | 1 (4/16) | 25%
Headache^40^ | 1 (4/16) | 25%
Heart rate changes^40^ | 1 (4/16) | 25%
Gastrointestinal symptoms^40–44^ | 2 (59/64) | 25%–64.6%
Appetite decrease^40–44, 54, 55^ | 3 (54/128) | 27.1%–75%
Insomnia^40, 54, 55^ | 2 (26/80) | 22%–75%
Agitation/nervousness/restlessness^40, 54, 55^ | 2 (43/80) | 42%–100%
Challenging behavior^41–44, 54, 55^ | 3 (64/128) | 4.2%–88%
Diarrhea^54, 55^ | 1 (11/64) | 17%
Dizziness^40–44^ | 1 (3/48) | 6.3%
Placebo
Gastrointestinal symptoms^40^ | 1 (14/16) | 87.5%
Agitation/nervousness/restlessness^40, 54, 55^ | 2 (26/80) | 16%–100
EPS/impaired movement^40–44^ | 2 (11/65) | 8.2%–31%
Challenging behavior^40–44, 54, 55^ | 3 (35/129) | 6.1%–81%
Appetite decrease^40–44, 54, 55^ | 3 (18/129) | 6.1%–52%
Insomnia^40, 54, 55^ | 2 (11/80) | 6%–44%
Abdominal pain^54, 55^ | 1 (4/64) | 6%
Vomiting^54, 55^ | 1 (3/64) | 5%
Constipation^54, 55^ | 1 (3/64) | 5%
Headache^40^ | 1 (7/16) | 44%
Somnolence^40^ | 1 (7/16) | 44%
Skin changes^40^ | 1 (6/16) | 38%
Diarrhea^54, 55^ | 1 (2/64) | 3%
Dry mouth^40^ | 1 (4/16) | 25%

Note: The Handen study^54, 55^ collapsed harms of atomoxetine and atomoxetine plus parent training under atomoxetine and harms in the placebo and placebo plus parent training groups under placebo.

a Harms reported by more than one participant.

EPS = extrapyramidal symptoms; n = number

In a 20-week open label extension including 88 children from the 8-week study (42 from the treatment group and 46 from placebo), overall scores on the ADHD Rating Scale improved from the 8-week baseline to the 28 week followup (p=0.015); changes on the inattention subscale were not significant.

An earlier 6-week crossover RCT (moderate risk of bias) including children with ASD and ADHD reported significant improvements in hyperactivity associated with atomoxetine compared with placebo (effect size=0.90, p=0.04), but changes in inattention measures were not significantly different between groups.^40^ Investigators considered seven children (43%) to be responders to atomoxetine (25% improvement in ABC-Hyperactivity scale and CGI rating of very much improved or improved). Table 14 outlines outcomes.

Guanfacine. One RCT evaluating extended release guanfacine included mostly males with ASD and hyperactivity, impulsiveness, and distractibility and reported significant improvements in hyperactivity (effect size=1.67, p<0.001) in the treated group compared with placebo.^46^ Cognitive tests of working memory did not differ between groups (Table 14).

##### Harms of ADHD Medications

Methylphenidate. Methylphenidate was associated with changes in appetite and challenging and repetitive behavior at all doses (rates ranging from 5% to 50%) and with anxiety and insomnia (at lower doses). Five (out of 24) children discontinued an afternoon dose of medication because of irritability in one study,^45^ and 13 of 72 discontinued a second RCT due to irritability (n=6) or other adverse effects.^24–27^ Table 15 outlines harms.

Table 15 Harms/adverse effects in studies of methylphenidate

Harm/Adverse Event^a^ | N Studies Reporting Harm (# Participants With Harm/Total Participants) | Reported Rates Across Studies
Methylphenidate (0.125–0.21 mg/kg/day)
Repetitive language^45^ | 1 (13/24) | 54.2%
EPS/impaired movement^24–27, 45^ | 2 (6/90) | 4.6%–8%
Appetite decrease^24–27, 45^ | 2 (10/90) | 4.6%–29%
Anxiety^24–27, 45^ | 2 (7/90) | 4.6%–17%
Gastrointestinal symptoms^24–27, 45^ | 2 (6/90) | 4%–7.6%
Heart rate changes^24–27, 45^ | 2 (3/90) | 4%–4.6%
Headache^24–27, 45^ | 2 (4/90) | 3.0%–8%
Withdrawal^24–27^ | 1 (2/66) | 3.0%
Repetitive behavior^24–27, 45^ | 2 (20/90) | 3%–46%
Challenging behavior^24–27, 45^ | 2 (18/90) | 15.2%–33%
Insomnia^24–27, 45^ | 2 (14/90) | 10.6%–50%
Depression/sadness^24–27, 45^ | 2 (3/90) | 1.5%–8%
Somnolence^24–27, 45^ | 2 (2/90) | 1.5%–4%
Methylphenidate (0.24–0.35 mg/kg/day)
Repetitive language^45^ | 1 (12/24) | 50%
Hair/skin pulling^45^ | 1 (3/24) | 12.5%
Dry mouth^45^ | 1 (2/24) | 8%
Staring^45^ | 1 (2/24) | 8%
Withdrawal^24–27^ | 1 (4/66) | 6.1%
Self-injury behavior^24–27^ | 1 (3/66) | 4.6%
Somnolence^24–27, 45^ | 2 (5/90) | 4%–6.1%
EPS/impaired movement^24–27, 45^ | 2 (3/90) | 1.5%–8%
Challenging behavior^24–27, 45^ | 2 (25/90) | 25.7%–33%
Gastrointestinal symptoms^24–27, 45^ | 2 (9/90) | 7.6%–17%
Depression/sadness^24–27, 45^ | 2 (7/90) | 4.6%–17%
Appetite decrease^24–27, 45^ | 2 (25/90) | 24.2%–38%
Headache^24–27, 45^ | 2 (5/90) | 1.5%–17%
Anxiety^24–27, 45^ | 2 (7/90) | 1.5%–25%
Insomnia^24–27, 45^ | 2 (14/90) | 18.2%–50%
Repetitive behavior^24–27, 45^ | 2 (16/90) | 6%–50%
Methylphenidate (0.27–0.50 mg/kg/day)
Repetitive language^45^ | 1 (9/24) | 37.5%
Appetite decrease^24–27, 45^ | 2 (21/74) | 24%–38%
Insomnia^24–27, 45^ | 2 (21/74) | 24%–38%
Challenging behavior^24–27, 45^ | 2 (17/74) | 20%–29%
Gastrointestinal symptoms^24–27, 45^ | 2 (10/74) | 12%–12.2%
Hair/skin pulling^45^ | 1 (2/24) | 8.3%
Anxiety^24–27, 45^ | 2 (6/74) | 8%
Self-injury behavior^24–27^ | 1 (3/50) | 6.0%
Repetitive behavior^24–27, 45^ | 2 (12/74) | 6%–37%
Depression/sadness^24–27, 45^ | 2 (5/74) | 4%–8%
Headache^24–27, 45^ | 2 (4/74) | 4%–6%
Withdrawal^24–27^ | 1 (2/50) | 4%
EPS/impaired movement^24–27, 45^ | 2 (3/74) | 2%–8%
Somnolence^24–27, 45^ | 2 (2/74) | 1.5%–8%

a Harms reported by more than one participant.

EPS = extrapyramidal symptoms; N = number

Atomoxetine. During the 8-week treatment versus placebo phase in one RCT, 81.3 percent of children receiving atomoxetine compared with 65.3 percent of placebo participants reported at least one adverse event (p=ns) in one study; one child in the atomoxetine group discontinued due to fatigue.^41–44^ Significantly more treatment than placebo participants reported nausea (14 vs. 4), decreased appetite (13 vs. 3), fatigue (11 vs. 3), and early morning awakening (5 vs. 0, all p values <0.05). In the open-label extension phase, 11 of 88 participants withdrew from the study due to adverse effects. Adverse effects occurring in more than 10 percent of participants in the first 8 weeks of treatment included upper abdominal pain (12.5%), decreased appetite (18.2%), fatigue (18.2%), headache (20.5%), and nausea (13.6%). Most harms attenuated over time: during the open label phase, only headache continued to occur in more than 10 percent of participants (14.8%).

In another RCT, more children in the atomoxetine group had gastrointestinal symptoms, fatigue, and racing heart rate (p values <0.05) than did children in the placebo group.^40^ Four children receiving placebo had severe adverse events including restlessness, mood swings, decreased appetite; among those receiving atomoxetine severe events included rage requiring hospitalization in one child (leading to study withdrawal) and tiredness in another.

In an RCT comparing atomoxetine plus parent training with atomoxetine alone, placebo, and placebo plus parent training (see effectiveness outcomes reported in the section on Combination Medical and Behavioral Treatment), abdominal pain and decreased appetite occurred more frequently in the atomoxetine groups than in placebo groups (p values ≤0.07) as did greater issues with sleep onset (p=NS). One child in the atomoxetine group who received levetiracetam for seizures was hospitalized for a seizure, but investigators did not consider the event related to atomoxetine. Fifteen participants withdrew from the study due to adverse events, five of whom were receiving atomoxetine (8% of children receiving active medication). Table 16 outlines harms.

Guanfacine. Guanfacine was fairly well tolerated: four children withdrew from the trial (2 for adverse events and 2 for lack of efficacy), and one child had severe aggressive behavior that resulted in patient psychiatric hospitalization. Other side effects included fatigue, decreased appetite, drowsiness, dry mouth, emotional lability, and anxiety. Heart rate and blood pressure decreased in treated patients with attenuation over time. Table 17 outlines harms.

Table 17 Harms/adverse effects in studies of guanfacine

Harm/Adverse Event^a^ | N Studies Reporting Harm (# Participants With Harm/Total Participants) | Reported Rates Across Studies
Guanfacine-extended release (1–3 mg/day)
Gastrointestinal symptoms^46^ | 1 (24/30) | 80%
Somnolence^46^ | 1 (19/30) | 63.3%
Challenging behavior^46^ | 1 (18/30) | 60%
Appetite Decrease^46^ | 1 (13/30) | 43.3%
Dry mouth^46^ | 1 (12/30) | 40%
Anxiety^46^ | 1 (9/30) | 30%
Energy level changes^46^ | 1 (9/30) | 30%
Headache^46^ | 1 (9/30) | 30%
Insomnia^46^ | 1 (9/30) | 30%
Repetitive behaviors or language^46^ | 1 (6/30) | 20%
Infection/fever/cold/congestion symptoms^46^ | 1 (5/30) | 16.7%
Depression/sadness^46^ | 1 (4/30) | 13.3%
EPS/impaired movement^46^ | 1 (4/30) | 13.3%
Dizziness^46^ | 1 (3/30) | 10%
Self-injury behavior^46^ | 1 (3/30) | 10%
Silliness^46^ | 1 (3/30) | 10%
Sleep changes^46^ | 1 (3/30) | 10%
Appetite Increase^46^ | 1 (2/30) | 6.7%
Eye/vision changes^46^ | 1 (2/30) | 6.7%
Nightmares^46^ | 1 (2/30) | 6.7%
Skin changes^46^ | 1 (2/30) | 6.7%
Urinary changes^46^ | 1 (2/30) | 6.7%
Placebo
Repetitive language^45^ | 1 (12/24) | 50%
Infection/fever/cold/congestion symptoms^46^ | 1 (7/32) | 21.9%
Energy level changes^46^ | 1 (6/32) | 18.8%
Staring^45^ | 1 (4/24) | 17%
Silliness^46^ | 1 (5/32) | 15.6%
Headache^45, 46^ | 2 (7/56) | 12.5%
Skin changes^46^ | 1 (4/32) | 12.5%
Somnolence^45, 46^ | 1 (7/56) | 12.5%
Appetite Increase^46^ | 1 (2/32) | 6.3%
Dizziness^46^ | 1 (2/32) | 6.3%
Sleep changes^46^ | 1 (2/32) | 6.3%
Urinary changes^46^ | 1 (2/32) | 6.3%
Self-injury behavior^24–27^ | 1 (2/66) | 3%
Appetite decrease^24–27, 45, 46^ | 3 (5/122) | 3.0%–6.3%
Hair/skin pulling^45, 46^ | 2 (6/56) | 4%–9.4%
Depression^45, 46^ | 2 (7/56) | 3.1%–13%
EPS/impaired movement^24–27, 45, 46^ | 3 (4/122) | 1.5%–13%
Anxiety^24–27, 45, 46^ | 3 (7/122) | 3.0%–17.0%
Insomnia^24–27, 45, 46^ | 3 (10/122) | 1.5%–21%
Gastrointestinal^24–27, 45, 46^ | 3 (18/122) | 7.6%–34.4%
Repetitive behavior^24–27, 45, 46^ | 3 (25/122) | 3%–50%
Challenging behavior^24–27, 45, 46^ | 3 (30/122) | 3.0%–53.1%

a Harms reported by more than one participant.

EPS = extrapyramidal symptoms; mg = milligrams; n = number

### Studies of Combined Medical and Behavioral Treatments

#### Key Points

- Atomoxetine plus parent training or atomoxetine alone were both associated with improvements in ADHD, inattention, hyperactivity, noncompliance, and overall symptom severity compared with placebo, with improvements maintained over 24 weeks for most treatment responders. Differences between atomoxetine groups were not statistically significant for any outcome.
- Melatonin and melatonin plus cognitive behavioral therapy (CBT) both improved sleep-related outcomes.
- Folic acid plus Treatment and Education of Autistic and Related Communication Handicapped Children (TEACCH) treatment and folic acid alone both improved behaviors, with no statistically significant group differences.
- Bumetanide plus applied behavior analysis improved symptom severity and behavior more than applied behavior analysis alone.
- Stem cell transplantation plus rehabilitation therapy improved symptom severity, lethargy, and stereotypy more than umbilical cord blood cell transplant plus rehabilitation therapy or rehabilitation therapy alone.
- Given that combination therapies were investigated in single studies, we could not make conclusions about their effects on any outcomes (insufficient strength of evidence).

#### Overview of the Literature

Three RCTs^54–57^ and two nonrandomized trials^120, 121^ evaluated different medical treatments in combination with behavioral compared with another treatment or placebo. Studies had low,^54, 55, 57^ moderate,^121^ and high risk of bias^56, 120^ and included a total of 419 children (median=66/study) ranging in age from 3 to 14 years. One RCT comparing risperidone plus parent training with risperidone alone was included in our 2011 review but not in the present medical treatment update as it evaluates the effect of parent training;^126^ however, it is one of the few studies to compare a combination medical and behavioral treatment.

#### Detailed Analysis

Atomoxetine. A 10-week trial with a 24-week extension randomized children with ASD and ADHD symptoms to one of 4 arms: atomoxetine, atomoxetine plus parent training, placebo, or placebo plus parent training.^54, 55^ Families assigned to parent training received nine 60–90 minute training sessions addressing preventing behavior problems and behavioral reinforcement. After 10 weeks of treatment over 45 percent of children in each of the atomoxetine groups met the definition of response (>30% decrease [improvement] on measures of ADHD and symptom severity) compared with 29 percent in the placebo plus parent training group and 19 percent in the placebo group (p=0.015 for atomoxetine vs. placebo). More children in the atomoxetine groups improved on measures of noncompliance but differences compared with the placebo group were not statistically significant. Parent ratings of inattention, hyperactivity, and ADHD were significantly improved in active treatment groups compared with placebo alone (p values ≤0.05); teacher ratings improved in all groups from baseline to followup but group differences were not significant. Both parents and teachers rated children in the atomoxetine groups as significantly improved compared with the placebo group on noncompliance (Home Situations Questionnaire) (p values ≤0.05). Parents also rated children in the placebo plus parent training group as significantly improved on the ABC-Hyperactivity and Inappropriate Speech scales compared with placebo alone (p values ≤0.05). Differences between the atomoxetine plus parent training and atomoxetine alone groups were not statistically significant for any outcomes.

After 10 weeks of treatment, 117 of the 128 children in the 10-week trial entered a 24-week extension. Atomoxetine responders and nonresponders who originally been assigned to a placebo group continued or began atomoxetine and maintained parent training if originally assigned to it in the 10-week trial. At followup, analyses of the effects of parent training vs. no parent training showed no significant group differences on measures of symptom severity, ADHD, inattention, hyperactivity, and parent-rated irritability and hyperactivity, though improvements were typically greater with parent training. Twenty-six of 40 children (60%) who were responders to atomoxetine maintained response; 37 percent of placebo nonresponders had favorable ADHD outcomes and 34 percent had favorable noncompliance outcomes. Harms reported in this study are described in Table 16.

Melatonin. One 12-week RCT with low risk of bias compared cognitive behavioral therapy (CBT) alone, melatonin alone, CBT plus melatonin, and placebo in 160 children.^57^ CBT consisted of four 50-minute sessions focused on recognizing dysfunctional attitudes about sleep, parent-management of children’s sleep, and replacing poor sleep habits with appropriate behavior. All active treatment groups improved in most measures of sleep quality compared with the control group (p<0.01). In general, the combination group improved more than the others, followed by melatonin, and CBT. Scores for children who received melatonin alone improved on bedtime resistance, sleep onset delay, sleep duration, and night waking compared with the CBT group (p<0.001). Effect sizes ranged from medium to high. Sleep onset latency (time to fall asleep) and sleep efficiency (ratio of total sleep time to total time in bed) were reduced by 50 percent (sleep latency) or 85 percent (efficiency) in 85 and 63 percent of children in the combination group and 39 and 46 percent of children in the melatonin group, respectively. In the CBT arm, 10 percent of children met each criterion, and no children in the control arm achieved these percentages of reduced latency or improved efficiency.

Folic Acid. One 12-week nonrandomized trial (moderate risk of bias) compared folic acid supplementation plus the TEACCH program to the TEACCH program alone and reported no statistically significant differences between groups on measures of challenging behavior, symptom severity, and teacher-rated communication, though both groups typically improved from baseline.^121^

Bumetanide. In a high risk of bias, 12-week RCT comparing bumetanide plus daily applied behavior analysis and applied behavior analysis alone, children in the combination arm had significantly improved ABC, CARS, and CGI scores (p values <0.05).^56^

Stem Cell Transplantation. In one 24-week nonrandomized trial (high risk of bias) including 37 children received either rehabilitation therapy plus umbilical cord blood cell transplant, rehabilitation therapy plus stem cell transplant (4 intravenous or intrathecal transplants at 5–7 day intervals), or rehabilitation therapy alone.^120^ All children also received sensory integration and behavioral treatment. Symptom severity improved over time in all groups, with significantly greater improvements in the stem cell group compared with each of the other arms (p<0.05). CGI and total ABC scores also improved more in the stem cell group compared with the other groups. Lethargy/social withdrawal and stereotypy scales improved significantly more in the stem cell group compared with the other arms (p<0.05), but scores on the other individual ABC scales did not differ significantly.

### Studies of Nutritional Supplements or Specialized Diets

#### Key Points

- Four RCTs compared omega-3 fatty acid supplementation and placebo and three addressing the outcome reported no significant effects on challenging behaviors. Our confidence in this conclusion is low (low strength of evidence for no effect). We also have low confidence in the conclusion that omega-3 supplementation was associated with minimal harms (low strength of evidence).
- Despite the number of RCTs with low or moderate risk of bias addressing other agents, evidence was inadequate to make conclusions about all clinical efficacy and harms outcomes because few, small, underpowered studies addressed each diet or supplement (insufficient strength of evidence).
- While seven studies addressed variations of the gluten-free casein-free (GFCF) diet, studies addressed different outcomes and different approaches to restricted and control diets; thus, data were inadequate to make conclusions about the body of evidence (insufficient strength of evidence).
- Data were inadequate to allow conclusions about the relative effectiveness of the other dietary interventions (e.g., camels’ milk, gluten- or casein-containing challenge foods) compared with placebo (insufficient strength of evidence).

#### Overview of the Literature

We identified 19 RCTs (three reported in multiple publications)^58–65, 80–88, 104–107, 117, 128^ that evaluated the use of supplements or dietary manipulation to treat ASD symptoms. Two of these studies^117, 128^ were included in our 2011 review. Studies addressed nutritional supplements including omega-3 long-chain free fatty acid (FFA) supplementation,^80–82, 84^ methyl-B12 supplement,^83, 87^ digestive enzymes,^85, 117^ and L-carnitine.^86, 88^ Dietary interventions addressed in studies included GFCF diets,^58, 62–65, 104–107^ gluten/casein challenge foods,^59, 60^ and camels’ milk.^61^

Studies were conducted in the United States,^58, 60, 63, 80–83, 87, 88, 106, 107, 128^ Australia,^117^ Belgium,^59^ Denmark,^64, 65^ Egypt,^85, 86^ Iran,^62^ Holland,^84^ Norway,^104, 105^ and Saudi Arabia.^61^ Study treatment durations ranged from 7 days to 2 years, and sample sizes ranged from 12 to 92 (total N=732). Followup occurred immediately post-treatment in all studies. Four RCTs had low risk of bias,^58, 60, 81, 83^ 10 had moderate,^59, 63, 80, 82, 84–87, 106, 107, 117, 128^ and five had high risk.^61, 62, 64, 65, 88, 104, 105^

#### Detailed Analysis

Despite the number of RCTs with low or moderate risk of bias addressing supplements or diets, evidence is insufficient to determine their effects on any outcome in the short- or long-term. Most studies were small (median 30 total participants), short-term (ranging from 1 week to 7 months, with 24 months of treatment in one study). We provide brief summaries of reported outcomes by agent below. Appendix F includes summary tables with detailed findings.

##### Studies of Nutritional Supplements

###### Free Fatty Acid (Omega-3) Supplementation

Little evidence supports the effectiveness of FFA supplementation to improve core or associated ASD symptoms (Table 18). Three RCTs of omega-3 FFA versus placebo (low^81^ and moderate^80, 84^ risk of bias) reported no significant group differences on most measures of challenging behavior, communication, language, and adaptive behavior including the ABC, CGI, Peabody Picture Vocabulary Test, Pervasive Development Disorder Behavioral Inventory (PDD-BI), VABS, Behavior Assessment System for Children (BASC), and Social Responsiveness Scale.^80, 81, 84^ One study reported significantly improved scores in the placebo group compared with the omega-3 group on the BASC externalizing problems scale after 6 months of treatment,^84^ and another reported significant improvement in parent ratings of stereotypy and lethargy in children receiving omega-3 supplements compared with those receiving placebo, but teacher ratings were not significantly different.^80^

Table 18 Key outcomes in studies of omega-3 fatty acids

Author, Year, Study Design Groups (dose), N Enrollment/N Final Treatment Duration/Follow-up Timepoint Post-Treatment Risk of Bias | Outcome Measure/Baseline Scores, Mean ±SD | Outcome Measure/Post-Treatment Scores, Mean ± SD
Mankad 2015^84^ RCT G1: Omega-3 fatty acid (3.5 mL/day), 19/18 G2: Placebo, 19/19 6 months/EOT Moderate RoB | Baseline scores NR | Change from Baseline PDDBI – Autism Composite G1: −4.5 G2: −6.4 G1 vs G2: p=ns BASC – Externalizing G1: 3.2 G2: −3.0 G1 vs G2: p=0.02 CGI G1: NR G2: NR G1 vs G2:p=ns VABS G1: 2.8 G2: −0.2 G1 vs G2: p=ns Preschool Language Scale (PLS4) G1: 0.7 G2: −0.6 G1 vs G2: p=ns
Voigt 2014^82^ RCT G1: Docosahexaenoic acid (DHA) (500 mg/day), 24/19 G2: Placebo, 24/15 6 months/EOT Moderate ROB | CGI-I Parent NR BASC – Parent G1: 26.5 ± 7.1 G2: 30.3 ± 9.1 BASC – Teacher G1: 32.2 ± 7.6 G2: 38.5 ± 4.3 | CGI-I Parent 3 months G1: 4/21 (19) G2: 5/16 (31) G1 vs G2: p=ns 6 months G1: 5/18 (28) G2: 2/13 (15) G1 vs G2: p=ns CGI-I Investigator 3 months G1: 1/17 (6)) G2: 0/13 (0) G1 vs G2: p=ns 6 months G1: 0/18 (0) G2: 1/14 (7) G1 vs G2: p=ns EOT BASC – Parent G1: 26.3 ± 6.8 G2: 33.3 ± 9.7 G1 vs G2: p=0.04 BASC – Teacher G1: 33.6 ± 9.3 G2: 34.0 ± 5.6 G1 vs G2: p=0.02
Bent 2011^81^ RCT G1: Omega-3 fatty acid (1.3 g/day), 14/13 G2: Placebo, 13/12 12 weeks/EOT Low RoB | ABC –Hyperactivity G1: 16.8 ± 13 G2: 20.3 ± 8 PPVT G1: 72.2 ± 28 G2: 85.8 ± 12 EVT G1: 70.8 ± 33 G2: 86.4 ± 14 SRS G1: 76.9 ± 11 G2: 79.0 ± BASC-Externalizing G1: 53.8 ± 13 G2: 66.3 ± 25 BASC- Internalizing G1: 43.3 ± 10 G2: 50.1 ± 9 BASC-Behavioral G1: 60.9 ± 14 G2: 65.4 ± 3 BASC-Adaptive skill G1: 29.8 ± 9 G2: 31.9 ± 9 BASC-Hyperactivity G1: 61.8 ± 17 G2: 64.6 ± 7 | Mean change score ABC – Hyperactivity G1: 2.7 ± 4.8 G2: 0.3 ± 7.2 G1 vs G2: p=ns PPVT G1: 2.7 ± 11.6 G2: 1.9 ± 12.4 G1 vs G2: p=ns EVT G1: 2.2 ± 7.6 G2: 5.8 ± 5.7 G1 vs G2: p=ns SRS G1: −0.9 ± .5 G2: 1.7 ± 7.2 G1 vs G2: p=ns BASC-Externalizing G1: 0.1 ± 6.7 G2: 6.6 ± 30.4 G1 vs G2: p=ns BASC-Internalizing G1: 0.3 ± 6.6 G2: −2.9 ± 7.6 G1 vs G2: p=ns BASC-Behavioral G1: −1.1 ± 6.1 G2: −2.0 ± 4.9 G1 vs G2: p=ns BASC-Adaptive skill G1: 1.8 ± 6.8 G2: 0.8 ± 7.1 G1 vs G2: p=ns BASC-Hyperactivity G1: 2.1 ± 6.3 G2: 1.2 ± 5.8 G1 vs G2: p=ns

ABC = Aberrant Behavior Checklist; BASC = Behavior Assessment System for Children; CGI = Clinical Global Impression; EOT = end of treatment; EVT = Expressive Vocabulary Test; PPVT = Peabody Picture Vocabulary Test; ROB = risk of bias; SRS = Social Responsiveness Scale

Another moderate risk of bias RCT of dietary docosahexanoic acid (DHA) supplementation versus placebo reported improvement in parent-rated social skills on the BASC in children receiving placebo vs. those receiving DHA, while teachers rated communication as more improved in the treatment group compared with placebo.^82^ Scores on other measures including the CGI, ABC, and Child Development Inventory did not differ significantly between groups.

###### Digestive Enzyme Supplementation

Evidence is insufficient to determine if short-term digestive enzyme supplements affect ASD core or associated symptoms. Two RCTs with moderate risk of bias addressed digestive enzyme supplements compared with placebo: one evaluated a proteolytic enzyme supplement (Peptizyde)^117^ and the other a digestive enzyme supplement (Neo-Digestin).^85^ The Peptizyde RCT reported no significant differences in measures of behavior, sleep quality, or gastrointestinal symptoms, and no significant differences in adverse effects.^117^ In a 3-month trial of Neo-Digestin versus placebo, CARS scores improved significantly in the treatment group compared with placebo.^85^

###### Other Supplements

Two RCTs with low^83^ and moderate^87^ risk of bias addressed methyl B12 supplementation. CGI scores improved significantly in the methyl B12 group in one RCT (effect size=0.84, p=0.005), but studies reported few other significant group differences in measures of behavior or communication.^87^ In two RCTs addressing L-carnitine (moderate^86^ and high^88^ risk of bias), ASD severity scores improved significantly in the L-Carnitine group compared with placebo in one, but scores on other behavioral measures or measures of adverse effects did not differ between groups.^88^ In the second RCT, symptom severity did not differ between groups after 6 months of treatment.^86^

##### Studies of Dietary Manipulation

###### Gluten-Free Casein-Free Diets (GFCF)

Data to assess effects of GFCF diets are limited as dietary approaches and outcome measures varied among studies as did control diets and monitoring of adherence to GFCF diets. Four RCTs (in multiple publications) compared GFCF diets to either an unaltered diet,^64, 65, 104–107^ or a low sugar diet (Total N across studies=82).^63^ One 12-week RCT (moderate risk of bias) reported no significant differences between groups on measures of development or behavior (Mullen Scales of Early Learning, Child Behavior Checklist), though the control group improved significantly from baseline on visual reception, withdrawal, aggression, and attention subscales (p values <0.05) Another 12-week crossover RCT (moderate risk of bias) similarly reported no significant differences between groups on measures of symptom severity or language, though parents of 7 of the 15 children participating in the study reported improvements in language.^106, 107^ In a retrospective analysis of videotapes recorded during the study period, investigators found no significant group differences in verbal communication between children in the diet or control groups or between children whose parents reported language improvements after the study period and those whose parents did not.

A 12-month RCT (high risk of bias) including children with urinary peptide abnormalities reported significant improvements(unblinded parent-rated questions from the Diagnosis of Psychotic Behavior in Children questionnaire) in communication, resistance to communication, social isolation, repetitive or challenging behavior, and overall impairment in children on a GFCF diet compared with those on a usual diet (p values ≤0.007).^104, 105^ Children in the GFCF diet also improved significantly on tests of cognitive skills, motor skills, verbal and social communication, anxiety, and reaction to changes in environment and routine compared with control children (p values <0.05). Another high risk of bias RCT with 24-month followup of participants reported few differences in behavioral measures between children on a GFCF diet and those with no dietary restrictions;^64, 65^ scores on the Autism Diagnostic Observation Schedule (ADOS) and Gilliam Autism Rating Scale improved significantly in participants in the GFCF group vs. no diet group at 12 months, but scores were not different on any measure in a subset of participants followed for 24 months.

###### Gluten-Free Diets

One 6-week, high risk of bias RCT compared a gluten-free diet to a usual diet and reported significant improvements in gastrointestinal symptoms (stomachache, bloating, constipation) from baseline in the gluten-free diet group but not in the control group. Diarrhea did not improve significantly in either group. Stereotyped behavior, communication, social interaction, and ASD symptoms also improved from baseline in the gluten-free group (p values <0.02) but not in the control arm; differences in stereotyped behaviors and communication, but not social interaction, were significant between groups (p values ≤0.005). The study did not report other between-group comparisons.

###### Gluten-Free and Dairy-Free Diets

In a small, low risk of bias trial comparing a gluten and dairy free diet with a diet including both gluten and dairy, scores on measures of challenging behavior (hyperactivity, irritability, inattention) did not differ between groups after 4 weeks of therapy.^58^ Children in both groups had gastrointestinal symptoms (loose or hard stools, abdominal pain, p=NR).

###### Gluten and Casein Challenge Foods or Supplementation

Two small RCTs (low^129^ and moderate^59^ risk of bias) evaluated “challenges” of gluten or casein containing foods, but evidence is inadequate to determine if short-term gluten- casein containing foods affect ASD symptoms or gastrointestinal function. One RCT randomized children who were maintaining GFCF diets to foods with gluten, gluten and casein, or placebo foods.^60^ The study reported no significant group differences in measures of challenging behaviors or measures of sleep quality and stool frequency at any time point over the 30-week trial. Another RCT assessing effects of introducing gluten-casein containing foods versus placebo foods similarly reported no significant effects of added gluten or casein on behavior or gastrointestinal symptoms.^59^

###### Camel Milk

A single RCT (high risk of bias) compared boiled or raw camel’s milk with cow’s milk and reported no significant differences in ASD severity between groups after 2 weeks of treatment.^61^

##### Harms of Nutritional or Dietary Interventions

Studies that reported harms either reported no significant difference between the intervention group and the control group, or reported zero harms for each group. Appendix F includes detailed harms tables.

### Studies of Risperidone Adjuncts

#### Key Points

- Though 14 RCTs with low or moderate risk of bias compared risperidone plus an adjunct medication with risperidone plus placebo, few compared the same adjunct agents. Studies thus provide little evidence to inform treatment decisions and can be considered primarily as pilot efficacy trials.
- Most studies reported improvements in irritability with combined treatment compared with placebo plus risperidone, but data were inadequate to assess effects for all comparisons and outcomes given the heterogeneity of agents (insufficient strength of evidence).

#### Overview of the Literature

We identified 14 placebo-controlled RCTs addressing risperidone plus an adjunct medication (titrated to 0.5 to 3 mg/day based on body weight).^89–100, 118, 124^ Two of these studies were included in our 2011 review.^118, 124^ Study medications added to risperidone included celecoxib,^94^ Ginkgo biloba,^97^ memantine,^95^ topiramate,^98^ riluzole,^91^ buspirone,^92^ N-acetylcysteine,^90, 93^ amantadine,^96^ pioglitazone,^99^ pentoxifylline,^118^ galantamine,^100^ minocycline,^89^ and piracetam.^124^ Studies were short-term (≤ 10 weeks of treatment) with no longer term followup evaluation once treatment ended.

Studies included a total of 561 children ranging in age from 3 to 17 years. All studies were conducted in Iran.^90–100, 118, 124^ We considered 11 studies to have low risk of bias^90–100^ and two to have moderate risk of bias.^118, 124^

#### Detailed Analysis

Despite the number of RCTs with low or moderate risk of bias, studies present little evidence to inform treatment decisions and can be considered primarily as pilot efficacy trials. As noted, all studies were short-term and lacked followup past the end of treatment. Studies included few participants (median 40 total/study) and few examined the same adjunct agent or outcomes besides the ABC Irritability subscale. Only two studies^90, 93^ addressed the same outcomes with different doses of the same agent (N-acetylcysteine). All studies except one of gingko biloba added to risperidone reported significant improvements on the ABC-Irritability subscale in the adjunct groups compared with placebo plus risperidone; one study reporting only total ABC scores reported significant improvements in the adjunct group compared with placebo.^124^ We present a brief summary of key outcomes in each study below; Appendix F includes detailed tables of outcomes and harms. Harms typically did not differ between groups.

N-acetylcysteine. Two studies^90, 93^ compared the effect of different doses of N-acetylcysteine as an adjunctive therapy to risperidone vs. placebo plus risperidone in a total of 80 children with autistic disorder. By the end of treatment, the N-acetylcysteine groups had significantly greater reduction in irritability scores (p<0.035) than the placebo group in both the trials; in one RCT scores on the hyperactivity/noncompliance (p<0.05) subscales were also significantly improved in the N-acetylcysteine group.^90^ Other subscale scores did not differ between groups in either RCT. Adverse events were mild and transient, with a similar incidence in both trials.

Celecoxib. One RCT explored the effectiveness of adding celecoxib as an adjunct to risperidone vs. placebo plus risperidone in 40 children reported significant improvements on the ABC irritability, lethargy/social withdrawal, and stereotypy scales in the adjunct group compared with placebo plus risperidone.^94^ Hyperactivity/noncompliance or inappropriate speech did not differ between groups. The frequency of adverse effects as reported by parents was similar between the two groups. By week 10, complete response (50% reduction in irritability subscale) was achieved by 11 of the children in the celecoxib group compared with four (20%) in the placebo group (p=0.02).

Ginkgo Biloba. In one RCT comparing Ginkgo biloba plus risperidone with risperidone plus placebo, investigators found no significant differences between groups on any of the ABC subscales. Side effects were similar between groups.

Memantine. One RCT reported significant reduction in ABC subscale scores for irritability, stereotypic behavior, and hyperactivity in the memantine adjunct group compared with risperidone plus placebo (all p<0.01).^95^ No significant effects were found on the lethargy or inappropriate speech subscales. Frequency of side effects including extrapyramidal symptoms was similar between the two groups.

Riluzole. In one RCT including children with autistic disorder who responded suboptimally to previous medication, children treated with riluzole and risperidone had significantly greater improvement in four of the five ABC subscales (p<0.01) than those receiving placebo plus risperidone.^91^ Based on CGI-I scores, complete response was achieved by 11 children (55%) in the riluzole group compared with five (25%) in the placebo group (p=0.05). Among the 16 side effects observed, increased appetite and weight gain were more frequently reported in the riluzole group versus the placebo group (p≤0.03). All other side effects occurred at a similar frequency in both groups.

Buspirone. More children receiving buspirone plus risperidone had a ≥30% reduction in irritability score (81.2% vs. 38.9%, p<0.01, RR=2.1) than those receiving placebo and risperidone. Investigators reported no serious adverse events in either group, but the odds ratio for increased appetite was 2.61 (61.1% with buspirone vs. 35.3% with placebo). Other commonly reported adverse events were drowsiness (11.1%) and fatigue (11.1%) in the buspirone group and dry mouth (5.9%) by the placebo group.

Topiramate. In one RCT children in the topiramate adjunct group had significantly greater reduction in ABC-C subscale scores for irritability, stereotypic behavior, and hyperactivity/noncompliance (all p=0.04) than those receiving placebo.^98^ Frequencies of most side effects including extrapyramidal symptoms were similar, though somnolence (35% vs. 5%, p=0.04) and decreased appetite (35% vs. 5%, p=0.04) occurred more frequently in the topiramate-treated group than the placebo group.

Amantadine. In one RCT including children with severe disruptive symptoms, ABC-Irritability and Hyperactivity/Noncompliance scores were significantly improved in amantadine adjunct group compared with the placebo group (p≤ 0.03).^96^ By week 10, 17 (85%) of the children in the amantadine group compared with 13 (65%) in the placebo group had partial response (25% reduction in irritability subscale) (p=0.14), while complete response (50% reduction in irritability score) was achieved by 7 (35%) vs. 3 (15%) in the amantadine and placebo groups respectively (p=ns). None of the other ABC subscale scores differed between the groups by the end of treatment. Frequency of adverse effects did not differ between groups. Based on the improvement measured by CGI scale, a higher proportion of children in the amantadine group responded to treatment than those in the placebo group (50 % vs. 20%, p=0.047), with two and eight children judged to have very much improved and much improved respectively in the amantadine group compared with one and three children in the placebo group.

Pioglitazone. In one RCT children receiving pioglitazone adjunct had significant improvement in the ABC Irritability (p=0.03), Lethargy/social withdrawal (p=0.04) and Hyperactivity/noncompliance (p=0.04) subscale scores compared with the placebo group;^99^ scores on other measures did not differ between groups. More children in the adjunct group also had a partial response (≥25% reduction in irritability score) than did children receiving placebo (45% vs. 15%, p=0.04). Nine children (45%) in the pioglitazone group had complete response (≥ 50% reduction in irritability score) compared with 7 (35%) in the placebo group (p=ns). Adverse events were mild and transient with no group differences in the frequency.

Galantamine. In a trial evaluating galantamine or placebo in addition to risperidone, children in the galantamine adjunct group showed significantly greater improvement in ABC-Irritability (p=0.017) and Lethargy/social withdrawal (p=0.005) subscales than the placebo group.^100^ Reduction in other ABC subscale scores after treatment was similar between the groups. Sixteen children (80%) in the galantamine group had a complete response (≥ 50% reduction in the irritability subscale score) compared with 10 (50%) in the placebo group (p=0.047), while partial response (≥25% reduction in the ABC-I subscale) was reported in 90% in the galantamine and 65% in the placebo group, p=0.058. The investigators noted no serious adverse events. Both groups reported weight gain by the end of the trial, with no significant group difference.

Pentoxifylline. Scores on the ABC-Irritability, Lethargy/Social Withdrawal, Stereotypic behavior, Hyperactivity/Noncompliance, and Inappropriate Speech subscales were significantly better for the pentoxifylline adjunct group compared with placebo (p ≤ 0.0001) in one RCT.^118^ Frequency of side effects including extrapyramidal symptoms did not differ between groups.

Piracetam. Risperidone plus piracetem was associated with more improvement on the ABC-C total score than risperidone given with placebo in one RCT, with similar incidence of extrapyramidal symptoms and other adverse events.^124^

Minocycline. Improvements in ABC-Irritability and Hyperactivity scales were greater in children receiving minocycline+risperidone than in children receiving placebo+risperidone (p values ≤0.003), but scores on the other subscales did not differ significantly between groups in one RCT (low risk of bias).^89^ Adverse events (including sedation, appetite changes, and gastrointestinal issues) did not differ between groups (p values=NS)

### Studies of Hyperbaric Oxygen Therapy

#### Key Points

- Studies of hyperbaric oxygen using differing protocols reported conflicting results: no treatment effects in two RCTs and significant improvements in ASD symptoms in another.
- Data were inadequate to assess the effects of hyperbaric oxygen compared with placebo on ASD symptoms, language, or harms (insufficient strength of evidence).

#### Overview of the Literature

We identified three RCTs with low^67, 114^ and moderate^66^ risk of bias addressing hyperbaric oxygen compared with a sham treatment. Studies were conducted in the United States^67, 114^ and Thailand^66^ and included a total of 150 children between 2 and 14 years old. Treatment duration ranged from 20 days to 15 weeks with followup immediately post-treatment.

#### Detailed Analysis

Three RCTs of hyperbaric oxygen used different doses and reported inconsistent results (favorable effects associated with treatment in one and no significant effects in two). The RCTs included children with diagnoses of autistic disorder^67, 114^ or autism.^66^ Two studies used a 24 percent oxygen treatment^67, 114^ and a third used 100 percent oxygen;^66^ children continued concomitant treatments including behavioral and medical interventions instituted prior to the studies. Two studies of 80^67^ or 20^66^ hourly treatments reported no significant differences between groups on measures of symptom severity, language, and adaptive behavior.^66, 67^ In a third RCT including 40 treatment sessions, clinician-rated overall CGI scores, parent-rated language and eye contact measures, the ABC-Irritability subscale, and the Autism Treatment Evaluation Checklist (ATEC) sensory scale improved significantly in the hyperbaric oxygen group compared with the placebo group. Other ABC or ATEC subscale scores did not differ significantly between groups.^114^

##### Harms of Hyperbaric Oxygen

Studies typically noted that no significant harms occurred. One child had worsening asthma symptoms and discontinued treatment in one study,^114^ while 11 children in another experienced middle ear barotrauma that did not lead to discontinuation of the treatment session or the study.^66^ Across studies, one child withdrew due to seizures and one due to worsening asthma.

### Studies of N-acetylcysteine

#### Key Points

- Two small RCTs of N-acetylcysteine reported few significant treatment effects and few clinically significant harms.
- N-acetylcysteine had no effect on social skills outcomes in two small RCTs; harms of this agent were not clinically significant. Our confidence in these conclusions is low (low strength of evidence). Data were inadequate to assess effects on other outcomes (insufficient strength of evidence).

#### Overview of the Literature

Two RCTs with low^78^ and moderate^79^ risk of bias assessed N-acetylcysteine compared with placebo. Studies were conducted in the United States and Australia over 12 to 24 weeks and included a total of 123 children between 3 and 10 years old. Followup in both studies was immediately post-treatment.

#### Detailed Analysis

In one 12-week RCT (low risk of bias) comparing the utility of N-acetylcysteine with placebo, children treated with N-acetylcysteine had significant improvement on the ABC-Irritability subscale as compared with placebo-treated children (p<0.001);^78^ but effects on other behavioral and social measures did not differ. A second 24-week RCT (moderate risk of bias) included 98 children randomized to N-acetylcysteine or placebo and reported no group differences on any outcome assessed including social communication, adaptive behavior, symptom severity, or repetitive behavior.^79^ Table 19 outlines key outcomes.

Table 19 Key outcomes in studies of N-acetylcysteine

Author, Year Study Design Groups (Dose), N Enrollment/N Final Treatment Duration/Follow-Up Timepoint Post-Treatment Risk of Bias | Outcome Measure/Baseline Scores, Mean ± SD | Outcome Measure/Post-Treatment Scores, Mean ± SD
Dean 2016^79^ RCT G1: N-acetylcysteine (500 mg/day), 48/34 G2: Placebo (ND),50/37 6 months/EOT Moderate ROB | SRS-Total Score G1: 102.9 ± 26.4 G2: 99.7 ± 24.8 CCC-General Communication G1: 33.6 ± 13.1 G2: 34.7 ± 14.6 CCC-Social Interaction Deviance G1: 3.1 ± 8.5 G2: 3.3 ± 6.7 Repetitive Behavior Scale-Total Score G1: 28.5 ± 19.4 G2: 24.8 ± 14.1 CGI-Severity G1: 4.1 ± 1 G2: 4.2 ± 1 Developmental Behavior Checklist-Total Score G1: 57 ± 23.2 G2: 59 ± 27.6 | SRS-Total Score G1: 92.1 ± 29.3 G2: 88.7 ± 27.7 G1 vs G2, p=ns CCC-General Communication G1: 34.7 ± 11.9 G2: 41.5 ± 16.5 G1 vs G2, p=ns CCC-Social Interaction Deviance Change Score G1: 0.05 ± 8.4 G2: −2.2 ± 8.2 G1 vs G2, p=ns Repetitive Behavior Scale-Total Score G1: 24.3 ± 24.3 G2: 20.8 ± 16.3 G1 vs G2, p=ns CGI-Severity G1: 3.9 ± 1 G2: 3.6 ± 1 G1 vs G2, p=ns Developmental Behavior Checklist-Total Score G1: 43.9 ± 25.2 G2: 48.2 ± 18 G1 vs G2, p=ns
Hardan 2012^78^ RCT G1: N-acetylcysteine (900 mg up to 3 times/day), 15/134 G2: Placebo, 18/15 12 weeks/EOT Low ROB | ABC Irritability G1: 16.9±7.9 G2: 14.8±9.6 ABC Lethargy G1: 15.2±9.5 G2: 12.1±7.8 ABC Stereotypy G1: 9.1±5.5 G2: 8.9±6.5 ABC Hyperactivity G1: 23.4±9.0 G2: 23.8±9.3 ABC Inappropriate Speech G1: 4.9±3.2 G2: 4.1±3.7 RBS-R Stereotypies G1: 6.7±3.8 G2: 8.1±5.3 RBS Self-Injurious Behavior G1: 3.9±4.4 G2: 3.4±3.8 RBS Compulsions G1: 4.7±3.7 G2: 5.8±4.8 RBS Rituals G1: 5.3±3.7 G2: 6.6±4.5 RBS Sameness G1: 7.8±7.2 G2: 9.2±8.1 RBS Restricted G1: 4.7±3.4 G2: 5.2±3.7 SRS Total G1: 111.9±28.3 G2: 104.7±28.1 SRS Social Awareness G1: 12.7±3.4 G2: 13.5±3.7 SRS Social Cognition G1: 21.9±6.3 G2: 21.2±5.8 SRS Social Communication G1: 39.6±11.3 G2: 39.3±8.6 SRS Social Motivation G1: 16.6±6.3 G2: 16.9±6.5 SRS Autism Mannerisms G1: 21.7±5.6 G2: 21.4±7.3 CGI Severity G1: 5.1±0.7 G2: 5.3±0.8 | EOT ABC Irritability G1: 7.2±5.7 G2: 13.1±9.9 p<.001 ABC Lethargy G1: 11±9.4 G2: 8.3±7.7 p=.ns ABC Stereotypy G1: 5.6±5.7 G2: 8.0±7.0 p=ns ABC Hyperactivity G1: 12.4±11.4 G2: 21.0±11.5 p=ns ABC Inappropriate Speech G1: 2.5±2.6 G2: 3.6±3.6 p=ns RBS Stereotypies G1: 4.6±3.4 G2: 6.9±5.2 p= .014 RBS Self Injurious Behavior G1: 2.2±2.3 G2: 3.0±3.6 p=ns RBS Compulsions G1: 2.5±2.1 G2: 5.2±5.0 p=ns RBS Rituals G1: 4.3±3.4 G2: 5.6±4.9 p=ns RBS Sameness G1: 5.3±4.7 G2: 7.9±6.2 p=ns RBS Restricted G1: 3.5±2.3 G2: 4.8±3.6 p=ns SRS Total G1: 93.8±26.7 G2: 98.5±37.8 p=ns SRS Social Awareness G1:11.5±3.3 G2: 13.4±4.7 p=ns SRS social Cognition G1: 18.8±7.0 G2: 18.9±5.6 p=.037 SRS Social Communication G1: 33.3±10.9 G2: 34.5±14.5 p=.ns SRS Social Motivation G1: 13.0±4.7 G2: 14.5±7.0 p=ns SRS Autism Mannerisms G1: 16.0±6.1 G2: 20.3±6.9 p=.045 CGI Severity G1: 4.5±0.8 G2: 4.9±0.9 p=ns CGI Improvement G1: 2.9±1.1 G2: 3.2±.09 p=ns

ABC = Aberrant Behavior Checklist; CCC = Children’s Communication Checklist; CGI = Clinical Global Impression; EOT = end of treatment; RBS = Repetitive Behavior Scale; ROB = risk of bias; SRS = Social Responsiveness Scale

##### Harms of N-acetylcysteine

Adverse events also did not differ between groups in either study, though one noted treatment discontinuation of one participant related to worsening of irritability.^78^ Table 20 outlines harms.

Table 20 Harms/adverse effects reported in studies of N-acetylcysteine

Harm/Adverse Event | N Studies Reporting Harm (# Participants With Harm/Total Participants) | Reported Rates Across Studies
N-acetylcysteine
Gastrointestinal symptoms ^78, 79^ | 2 (23/48) | 26.5%–100%
Agitation/nervousness/restlessness ^78^ | 1 (3/14) | 21.4%
EPS/impaired movement ^78^ | 1 (3/14) | 21.4%
Appetite decrease ^78^ | 1 (2/14) | 14.3%
Appetite increase ^78^ | 1 (2/14) | 14.3%
Skin changes^79^ | 1 (2/34) | 5.9%
Asthma^79^ | 1 (1/34) | 2.9%
Cysts – Unspecified^79^ | 1 (1/34) | 2.9%
Infection/fever/cold/congestion symptoms ^78, 79^ | 2 (20/48) | 2.9%–28.6%
Placebo
Appetite decrease^78^ | 1 (3/15) | 20%
Drooling/increased saliva^78^ | 1 (2/15) | 13.3%
Skin changes^79^ | 1 (2/37) | 5.4%
Cysts – Unspecified^79^ | 1 1(/37) | 2.7%
Agitation/nervousness/restlessness^78, 79^ | 1 (3/15) | 6%–13%
EPS/impaired movement^78^ | 1 (3/15) | 6%–13%
Gastrointestinal symptoms^78, 79^ | 2 (17/52) | 6%–21%
Infection/fever/cold/congestion symptoms^78, 79^ | 2 (21/52) | 2.7%–40%

EPS = extrapyramidal symptoms; N = number

### Studies of Tetrahydrobiopterin

#### Key Points

- Two small RCTs reported inconsistent effects of tetrahydrobiopterin on symptom severity and few clinically significant harms.
- Tetrahydrobiopterin had no effect on symptom severity and was not associated with clinically significant harms. Our confidence in these conclusions is low (low strength of evidence). Data were inadequate to assess effects on other outcomes (insufficient strength of evidence).

#### Overview of the Literature

Two RCTs with low^53^ and moderate^103^ risk of bias compared tetrahydrobiopterin and placebo. The studies included 56 children between 3 and 7 years old and ranged from 16 to 24 weeks duration with followup immediately post-treatment. Studies were conducted in the United States and Sweden.

#### Detailed Analysis

In one 16-week RCT (low risk of bias) comparing tetrahydrobiopterin and including children with VABS developmental quotients of at least 50, children in the treatment arm had better language, adaptive behavior, and social interaction skills at baseline compared with placebo participants.^53^ At followup immediately post-treatment, scores on the primary outcome, the CGI, were not significantly different between groups. Secondary outcomes favored the treatment group: children in the treatment group improved significantly more on the ABC Irritability, Lethargy, Stereotypy, Hyperactive and Inappropriate Speech scales; Social Responsiveness Scale (SRS) total and subscale scores; and VABS composite and subscale measures than did children in the placebo group (p values <0.00).

In another 24-week crossover RCT (moderate risk of bias) including 12 boys, overall CARS scores did not differ significantly between group. In a post-hoc analysis grouping CARS variables into those assessing social interaction, communication, and stereotypy, children in the treatment group had significant improvement in social interaction (p=0.04) but not in the other categories.^103^ Table 21 outlines key outcomes.

Table 21 Key outcomes in studies of tetrahydrobiopterin

Author, Year Study Design Groups (Dose), N Enrollment/N Final Treatment Duration/Follow-Up Timepoint Post-Treatment Risk of Bias | Outcome Measure/Baseline Scores, Mean ± SD | Outcome Measure/Post-Treatment Scores, Mean ± SD
Klaiman 2013^53^ RCT G1: Tetrahydrobiopterin (20mg/kg/day), 23/23 G2: Placebo (NA), 23/23 16 weeks/EOT Low RoB | CGI-Severity [N (%)] Frequency of markedly, severely, or extremely ill G1: 10 (48) G2: 15 (68) ABC-Irritability G1: 11.1 ± 7.7 G2: 11.9 ± 7.8 ABC-Social withdrawal/lethargy G1: 9.5 ± 7.5 G2: 16.2 ± 10.0 ABC-Stereotypy G1: 6.1 ± 3.9 G2: 6.1 ± 3.6 ABC-Hyperactivity G1: 21.5 ± 10.3 G2: 22.9 ± 11.6 ABC-Inappropriate speech G1: 3.7 ± 2.4 G2: 3.4 ± 4.1 SRS G1: 81.4 ± 10.3 G2: 83.6 ± 9.2 PLS G1: 77.8 ± 29.2 G2: 57.1 ± 25.7 VABS G1: 320.5 ± 47.9 G2: 274.4 ± 51.4 | 16 wks follow-up CGI-Severity [N (%)] Frequency of markedly, severely, or extremely ill G1: 7 (35) G2: 14 (64) G1 vs G2: p=ns Improvement, frequency of very much or much improved G1: 5 (25) G2: 3 (14) G1 vs G2: p=ns ABC-Irritability G1: 10.0 ± 7.8 G2: 10.8 ± 7.8 G1 vs G2: p=ns ABC-Social withdrawal/lethargy G1: 5.2 ± 4.4 G2: 13.6 ± 7.5 G1 vs G2: p<0.01 ABC-Stereotypy G1: 5.4 ± 3.8 G2: 6.7 ± 4.5 G1 vs G2: p=ns ABC-Hyperactivity G1: 18.2 ± 8.5 G2: 22.8 ± 10.3 G1 vs G2: p=ns ABC-Inappropriate speech G1: 2.6 ± 1.9 G2: 3.9 ± 3.6 G1 vs G2: p=ns
Klaiman 2013^53^ RCT, continued G1: Tetrahydrobiopterin (20mg/kg/day), 23/23 G2: Placebo (NA), 23/23 16 weeks/EOT Low RoB | | SRS G1: 76.7 ± 10.9 G2: 83.2 ± 10.4 G1 vs G2: p=ns PLS G1: 84.0 ± 28.8 G2: 60.4 ± 25.4 G1 vs G2: p=0.01 VABS G1: 344.76 ± 50.0 G2: 294.9 ± 70.1 G1 vs G2: p=0.02
Danfors 2005^103^ RCT G1: Tetrahydrobiopterin/Placebo (3mg/kg),12 G2: Placebo/Tetrahydrobiopterin (ND), 12 12 months/EOT Moderate ROB | CARS-Total Score G1: 35.4 ± 2.6 G2: 37.4 ± 7.1 Social Interaction G1: 9 ± 0.6 G2: 10.8 ± 1.6 | Points Decreased CARS-Total Score G1: 2.1 ± 2.1 G2: 2.1 ± 4.3 G1 vs G2, p=ns Social Interaction G1: 1.6 ± 1.1 G2: 0.3 ± 1.4 G1 vs G2, p=0.04

ABC = Aberrant Behavior Checklist; CARS = Childhood Autism Rating Scale ; CGI = Clinical Global Impression; EOT = end of treatment; N = number; NR = not reported; NS = not significant; PLS = Preschool Language Scale; SRS = Social Responsiveness Scale; ROB = risk of bias; VABS = Vineland Adaptive Behavior Scales

##### Harms of Tetrahydrobiopterin

Several children in both groups reported sleeping problems and behavioral issues, but investigators did not consider any harms to be clinically significant, and no child withdrew from either study due to adverse events. Table 22 outlines harms.

Table 22 Harms/adverse effects reported in studies of tetrahydrobiopterin

Harm/Adverse Event | N Studies Reporting Harm (# Participants With Harm/Total Participants) | Reported Rates Across Studies
Tetrahydrobiopterin
Sleeping problems^103^ | 1 (4/5) | 80%
Agitation/nervousness/restlessness^103^ | 1 (3/5) | 60%
Challenging behavior ^53^ | 1 (4/20) | 22%
Hyperactivity ^53^ | 1 (2/20) | 9%
Insomnia ^53^ | 1 (2/20) | 9%
Skin changes ^53^ | 1 (2/20) | 9%
Placebo
Sleeping problems^103^ | 1 (5/6) | 83.3%
Agitation/nervousness/restlessness^103^ | 1 (3/6) | 50%
Challenging behavior^53^ | 1 (4/22) | 17%
Insomnia^53^ | 1 (4/22) | 17%
GI symptoms^53^ | 1 (4/22) | 17%
Repetitive behavior or language^53^ | 1 2(/22) | 9%
Seizure^53^ | 1 (1/22) | 4.5%
Hyperactivity^53^ | 1 (1/22) | 4%

N = number

### Studies of Other Medical Interventions

#### Key Points

- Most agents or interventions were addressed in only one study.
- While most studies reported some positive treatment effects on sleep, ASD symptoms, or language, data were inadequate to assess any comparisons given the heterogeneity of interventions (insufficient strength of evidence).

#### Overview of the Literature

We categorized studies as “other” if we could not assess strength of evidence for interventions and outcomes reported (i.e., insufficient strength of evidence) and the studies did not fall under a broader category of intervention such as diet or nutritional supplements. Fourteen studies (13 RCTs and 1 retrospective cohort study) addressed other medical interventions.^22, 23, 57, 68–75, 77, 100, 108, 115, 116, 123^ Most agents or interventions were addressed in only one study. Two studies evaluated donepezil.^77, 116^ Agents or interventions addressed in single studies included melatonin,^68^ bumetanide,^72^ transcranial stimulation (addressed in one multi-publication RCT^69, 70^), amantadine,^115^ citalopram,^22, 23^ divalproex,^74^ oxytocin,^71^ mecamylamine,^73^ memantine,^75^ prednisolone,^123^ and levetiracetam.^108^

Three studies were included in our prior review,^23, 115, 116^ including one RCT that now includes a followup analysis.^22, 23^ We considered six studies to have low risk of bias,^22, 23, 57, 73–75, 108^ seven to have moderate risk,^68–72, 77, 115, 116^ and one to have high risk.^123^

Studies included a total of 829 children (median 39 total children/study) between the ages of 2 and 19 years receiving treatment for 4 days to 9 months. Two studies reported followup after the end of treatment (1–3 months post-treatment).^71, 72^

#### Detailed Analysis

Despite the number of RCTs with low or moderate risk of bias, studies present little evidence to inform treatment decisions and can be considered primarily as pilot efficacy trials. Most studies were short-term and lacked followup past the end of treatment. Studies included few participants and few examined the same agents. Two studies addressed donepezil but examined different outcomes. Harms reported in studies comparing these interventions were diverse, and their clinical significance is difficult to determine given the short-term nature of the studies and the typically low numbers of participants. Gastrointestinal symptoms including constipation, diarrhea, and abdominal pain occurred frequently as did agitation, nervousness, or restlessness and appetite changes. We present a brief summary of key effectiveness outcomes in each study below; Appendix F includes detailed tables of outcomes and harms.

Donepezil. Two RCTs (moderate risk of bias) of donepezil assessed differing outcomes and reported no effects on executive function and treatment-associated improvements in language. In an RCT comparing donepezil and placebo, changes between groups on measures of executive function did not differ significantly after 10 weeks of treatment, though each group generally improved on each measure over time.^77^ In a 10-week open label extension, participants generally improved slightly on most measures (differences between baseline and 5 mg or 10 mg doses not significant). Scores on verbal and nonverbal problem solving skills and flexibility of thinking worsened over time (baseline vs. 10-mg dose, p ≤0.004). In another crossover RCT addressed in our prior review,^11^ children receiving donepezil versus placebo improved on clinician-rated measures of receptive and expressive language and symptom severity after 6 weeks of treatment (p values <0.05).^116^

Citalopram. One low risk of bias RCT (reported in multiple publications) addressed the serotonin reuptake inhibitor citalopram and reported no significant effects on repetitive behavior and some positive effects on challenging behaviors compared with placebo.^22, 23^ The original study was included in our 2011 review and now includes a followup study examining potential predictors of response to citalopram (see KQ2).^22, 23^ The study (low risk of bias) focused on repetitive behavior outcomes in children with PDD and significant repetitive behavior. Investigators reported no significant differences between citalopram and placebo arms on measures of repetitive behavior, with similar baseline scores on the CYBOCS and similar improvements in each arm. The other measures of repetitive behavior, including the Repetitive Behavior Scale-Revised, also had similar improvements in each arm with no evidence for an effect of citalopram. The CGI-Improvement scale similarly showed no significant difference between the citalopram and the placebo arm. On the other hand, the primary measure of challenging behavior reported in this trial, the ABC-Irritability subscale, showed an advantage for citalopram with more improvement in the citalopram arm than for placebo.

Memantine. One low risk of bias RCT included a 12-week, placebo-controlled phase to determine safety and tolerability of memantine and a 48 week extension (6 weeks dose titration, with placebo participants moving to memantine followed by 42 weeks of maintenance treatment).^75^ Both groups improved from baseline on caregiver-rated social skills (Social Responsiveness Scale) and on an unvalidated scale that measured symptom severity (Core Autism Treatment Scale-Improvement). Improvements were maintained over the extension period, but differences between groups at 12 weeks were not significant. Group differences on other measures of behavior and language (e.g., ABC, Children’s Communication Checklist) were not statistically different between groups.

Levetiracetam. One 10-week, low risk of bias RCT reported no significant group differences in parent- or teacher-rated ABC scores, overall symptoms (CGI), impulsivity/hyperactivity, or repetitive behavior, though repetitive behavior improved in both groups from baseline.^108^

Mecamylamine. One low risk of bias, 14-week RCT randomized children to either mecamylamine in ascending doses (up to a maximum 5 mg/day) or placebo and reported no significant differences between groups on any of the outcome measures.^73^

Divalproex Sodium. In a 12-week RCT with low risk of bias including children with ASD and significant irritability or aggression, children receiving divalproex had greater improvements in the CGI-Irritability and ABC-Irritability scales (p values <0.05), but scores on measures of aggression and repetitive behavior (Overt Aggression Scale-Irritability, CYBOCS) did not differ between groups.^74^ In exploratory analyses changes in adaptive behavior or manic symptoms also did not differ between groups.

Melatonin. A crossover RCT with moderate risk of bias compared melatonin or placebo for 3 months followed by a 1-month washout and 3 months of either melatonin or placebo.^68^ Sleep latency and total sleep were significantly reduced in the melatonin group compared with placebo (p≤.004), but night wakings did not differ between groups. Similarly, scores on the dysomnia scale of the Sleep Difficulties Questionnaire, but not the other sub-scales, were significantly lower for the treatment group compared with placebo (p=.041). Scores on the Developmental Behavior Checklist were significantly different between groups (mean difference=6.0, p=0.05), with lower scores (improved behavior) in the melatonin group.

Bumetanide. One RCT with moderate risk of bias compared bumetanide or placebo for 3 months followed by repeat evaluations 1 month after the end of treatment.^72^ After the 3 month treatment period, CARS scores for participants in the treatment group declined from the severe range to medium or mild severity. At the 120 day followup, scores had shifted back toward pre-treatment values in both groups (p=ns). CGI scores were significantly improved in the treatment group compared with placebo at 120 days (p=0.02), but ADOS total scores did not differ between groups. In analyses removing children with the most severe symptoms, ADOS scores improved significantly in the treatment group (p=0.03).

Amantadine. One moderate risk of bias RCT of amantadine reported no significant effect of daily amantadine over 4 weeks on parent-rated ABC behavior scores and clinician-rated CGI rating of overall improvement compared with placebo.^115^ However, children in the amantadine arm improved significantly more than those receiving placebo in clinician-rated ABC Hyperactivity and Inappropriate Speech subscales.

Oxytocin. One RCT with moderate risk of bias including 38 boys with IQs of at least 80 and comorbid ADHD, oppositional defiant disorder, or anxiety compared four doses of nasal oxytocin or placebo over 5 days.^71^ Children also received an emotion recognition training program and completed family interaction tasks both before and after oxytocin administration. No outcomes (social interaction, repetitive behavior, emotion recognition, ASD severity) differed between groups on blinded investigator-, parent-, and observation coder-ratings.

Prednisolone. In one retrospective study (high risk of bias) including children considered to have “regressive” autism (defined as clinically determined loss of age-appropriate language, communication, cognitive abilities and behavior), children who received prednisolone (mean treatment duration of 9.13±3.26 months, range=4–14 months) improved significantly more on a parent- and clinician-rated measure of receptive and expressive language developed for the study.^123^ In followup of treated participants approximately 12 months after the end of treatment, participants with improved language (n=17) maintained or increased their improvements; three nonresponders continued to have no change in language in parent reports.

Transcranial Stimulation. One RCT with moderate risk of bias assessed transcranial direct current stimulation using electrodes attached to the scalp to provide positive and negative electrical currents to putatively affect activity in regions of the brain that may play a role in ASD symptoms.^69, 70^ Investigators allocated study participants (all males) with mild to moderate ASD to either active stimulation (2 sessions of roughly 20 minutes) or sham simulation. At 7 days post-treatment, mean clinician-rated CARS scores and parent-rated ATEC total, social, sensory, and health and behavioral problem (but not language) scores were significantly improved in the treatment group compared with placebo (p values <0.05) Scores on the clinician-rated CGAS were also more improved in the treatment group (p<0.05) but CGI-Severity scores did not differ between groups. Investigators rated 45 percent of children receiving active treatment and 15 percent receiving sham treatment as “much improved” (p<0.05) and 10 percent in each arm as “much worse” (p=NS).

## KQ2 Modifiers of Treatment Outcomes

Understanding the degree to which child characteristics (i.e., age, specific ASD-related difficulties and skills), treatment factors (e.g., type, duration, intensity), and systems (e.g., family, community) influence response to treatments could improve targeting of treatments to the appropriate children and circumstances. While we sought modifying effects of child, provider, or intervention characteristics, few studies reported modifiers, and few were likely adequately powered to detect effects. We report modifying variables addressed in studies meeting our criteria as an indication of potential characteristics that may affect findings.

Antipsychotics. A sub-analysis of an 8-week RCT of risperidone vs. placebo^34^ analyzed mediators and moderators of the decrease in irritability.^29^ Baseline ABC-Irritability subscale score severity was the only significant moderator found. High severity was associated with greater improvement in irritability than was low severity in improvement with risperidone. Weight gain was the only significant mediator of response to risperidone. Greater weight gain was associated with less irritability improvement in the risperidone group. In an analysis of dose and compliance, better compliance was found to be associated with more improvement in the risperidone group and greater dose was associated with greater improvement.

In another post-hoc analysis of data from an extension of the 8-week trial of risperidone, younger age and better communication skills were associated with greater gains in communication but not with gains in daily living skills or socialization as measured on the VABS.^37^ No child characteristics were associated with gains in adaptive behavior and gains in each domain of adaptive behavior (e.g., communication, socialization) appeared to contribute equally to gains in the overall adaptive behavior score. Reductions in aggression were also not associated with the magnitude of gains in adaptive behavior.

An additional analysis of this study analyzed the effect of initial severity of ASD on the efficacy of risperidone.^110^ This study found that parent-, but not clinician-, efficacy of risperidone on irritability and lethargy was greater with higher baseline measurements of severity (moderate through severity) of challenging behaviors. Effects of baseline severity on clinician-rated ABC or CGI scores or parent ratings of other ABC scales (stereotypy, hyperactivity, inappropriate speech) were not statistically significant.

In secondary analyses of one RCT comparing aripiprazole and placebo, Caucasian children receiving aripiprazole had a relapse rate of 25.8 percent compared with 60.7 percent in the placebo group (HR=0.33, 95% CI: 0.14 to 0.78, p=0.01). Among non-White patients, the difference was not statistically significant. Age also did not interact significantly with relapse.^48^ Finally, in one retrospective cohort study primarily assessing BMI change in children taking either risperidone or aripiprazole, investigators found no variables (baseline BMI or age, race, gender, intellectual disability, concomitant drug use, treatment duration) to be significant covariates of BMI Z-score change per year of treatment.^122^

ADHD Medications. In a double-blind cross-over trial of methylphenidate in 66 children,^24–27^ authors found no effect of age, IQ, weight, or diagnosis on teacher- or parent-rated hyperactivity subscale scores, Swanson Nolan and Pelham rating scale (SNAP-IV), or CYBOCS scores. Children with Asperger syndrome/PDD-NOS (n=19) showed a trend of being more likely to be classified as responders to both placebo and methylphenidate than those with autism. Response to each dose of methylphenidate was significantly superior to placebo in the autism subgroup but not for the Asperger/PDD-NOS subgroup. In a later analysis assessing gene variants potentially associated with response, variations in seven genes (SLC6A4, SLC6A3, DRD1, DRD3, DRD4, COMT and ADRA2A) that influence monoaminergic signaling were significant predictors, though the study was not powered to correct for multiple comparisons.^24^ In another RCT comparing guanfacine and placebo, cognitive skills were not significantly associated with treatment effects.^46^

Other Agents. Studies of other agents reported various potential modifiers of effects: Response to placebo (but not citalopram) was predicted by severity of disruptive behaviors, particularly hyperactivity, ASD severity and mood, and caregiver strain (p values ≤.012) in one study.^22, 23^ Children with higher baseline scores on these measures exhibited less response to placebo. In a trial of atomoxetine, scores on tests of inhibition control (go-no go task) and degree of distractibility by irrelevant information (focused-attention task) were not significantly correlated and did not correlate with changes in measures of ADHD symptoms.^41–44^

In a trial of divalproex, analyses suggested that children with abnormal epileptiform electroencephalogram (EEG) results were more likely to respond to divalproex than those with normal EEGs.^74^ In analyses of treated children in this trial (n=16), children with higher blood levels of valproate (87–100 mcg/ml) had a better response rate, and higher dose was associated with a moderate effect on improvement scores (p values=NR).

Higher IQ was significantly correlated with improvements in social interaction in a post-hoc analysis in a crossover RCT comparing tetrahydrobiopterin and placebo.^103^ Age or total CARS scores were not significantly associated with improvements. In a trial of buspirone, children with fewer brain abnormalities in positron emission tomography scans had significantly more behavioral improvement than those with fewer, as children with normal (not elevated) blood serotonin levels ( values ≤0.04); the serotonin association was not significant in multiple regression analysis.^76^ In one RCT comparing hyperbaric oxygen and sham treatment, older age (> 5 years) and lower baseline symptom severity as measured on the ADOS were associated with better outcomes.^114^

An RCT comparing active and sham transcranial stimulation reported that increased left frontal lobe activity as indicated by increases in peak alpha frequencies was associated with improvements in ATEC measures of social problems and health and behavior problems.^69, 70^ Few of the included trials of diet or supplement interventions: one trial of gluten-free diet compared with a regular diet reported no significant correlations between baseline behavioral or gastrointestinal measures and outcomes.^62^ In a trial of methyl-B12, improvement was positively correlated with increases in plasma levels of methionine an decreases in S-adenosylmethionine, and the ratio of these two levels (p values ≤0.05).^87^

No studies of risperidone adjuncts reported modifiers of effectiveness.

## KQ3 Time to Effect of Interventions

Information about early response to treatment, or lack thereof, could guide treatment selection, implementation, and modification; however, no studies reported data to assess time to effect of interventions. While several studies reported changes in the number of children responding to a given agent over time, studies did not provide data to determine the initiation of effects. One study of aripiprazole noted that clinically important improvements were seen within 8 weeks of treatment, but treatment was not associated with delayed relapse (return of significant symptoms by 16 weeks of treatment/placebo) compared with placebo.^48^ In one study comparing risperidone and aripiprazole, improvement with aripiprazole was evident in the first 12 weeks of treatment without additional improvements at 24 weeks, while scores on measures in children taking risperidone improved at 12 weeks and continued to improve over the 24 week period.^50^ The study does not indicate, however, when effects began to be observed. Another study assessing transcranial stimulation reported changes in peak alpha frequency immediately post-treatment in children receiving active versus sham stimulation (significant change from baseline in active treatment group and significant between group differences at some electrode sites), but the clinical effects of such changes are not clear.^69, 70^

## KQ4 Evidence that Effects Measured at the End of Treatment Predict Long-Term Functional Outcomes

Few studies provided data to address this KQ. Few studies had longer-term followup and those with more than 6 months of treatment or followup typically did not report functional outcomes. In one study, risperidone use was not associated with changes in IQ.^28^ Changes from baseline to the end of study in class assignment (e.g., special education, regular classroom) were not significant.

## KQ5 Effectiveness Across Environments or Contexts

Seven studies reported teacher ratings of outcome measures that provide some information to address this KQ, but the limited results preclude conclusions. One RCT of omega-3 fatty acids reported no significant group differences in teacher ratings of challenging behaviors (parents also rated few measures as improved),^80^ while another RCT of DHA supplementation versus placebo reported improvement in parent-rated social skills in children receiving placebo vs. those receiving DHA, while teachers rated communication as more improved in the treatment group compared with placebo.^82^ An RCT of gluten- or casein- containing challenge foods introduced to a gluten-free diet reported no statistically significant changes in behavior as rated by parents or teachers on the Connors scale.^60^ An RCT of levetiracetam vs. placebo reported no significant group differences on any parent- or teacher- rated measures but also noted that teachers, but not parents, rated children in the placebo arm as more improved on irritability compared with the levetiracetam group (p=0.003).^108^

RCTs of methylphenidate reported general agreement between parent and teacher ratings of hyperactivity.^24–27, 45^ In one RCT, both parents and teachers considered hyperactivity and impulsive behavior to be significantly improved in the treatment group compared with placebo, but teachers (vs. parents) reported no significant group differences in inattention or oppositional behavior. Finally, one RCT of atomoxetine reported significant teacher-rated improvements in hyperactivity in the atomoxetine group compared with placebo, but teacher ratings of cognitive problems/inattention, oppositional behavior, or overall ADHD symptoms did not differ between groups.^41–44^ In another RCT comparing atomoxetine alone, atomoxetine + parent training, placebo alone, and placebo + parent training, parents, but not teachers, rated children in active treatment groups as significantly improved on measures of ADHD, inattention, hyperactivity, and oppositional behavior.^54, 55^

## KQ6 Drivers of Treatment Outcomes

We did not identify studies that provided data to address this KQ.