# References

1 Christensen DL, Baio J, Braun KV, . Prevalence and Characteristics of Autism Spectrum Disorder Among Children Aged 8 Years - Autism and Developmental Disabilities Monitoring Network, 11 Sites, United States, 2012. MMWR Surveill Summ. 2016;65(3):1–23. doi: 10.15585/mmwr.ss6503a1. PMID: 27031587.27031587
2 Seltzer MM, Shattuck P, Abbeduto L, . Trajectory of development in adolescents and adults with autism. Ment Retard Dev Disabil Res Rev. 2004;10(4):234–47. doi: 10.1002/mrdd.20038. PMID: 15666341.15666341
3 Ospina MB, Krebs Seida J, Clark B, . Behavioural and developmental interventions for autism spectrum disorder: a clinical systematic review. PLoS One. 2008;3(11):e3755. doi: 10.1371/journal.pone.0003755 [doi]. PMID: 19015734.19015734
4 Seida JK, Ospina MB, Karkhaneh M, . Systematic reviews of psychosocial interventions for autism: an umbrella review. Dev Med Child Neurol. 2009 Feb;51(2):95–104. doi: DMCN3211 [pii] 10.1111/j.1469-8749.2008.03211.x [doi]. PMID: 19191842.19191842
5 Parr J. Autism BMJ Clin Evid 2010;2010 PMID: 21729335.21729335
6 Wan Yunus F, Liu KP, Bissett M, . Sensory-Based Intervention for Children with Behavioral Problems: A Systematic Review. J Autism Dev Disord. 2015 Nov;45(11):3565–79. doi: 10.1007/s10803-015-2503-9. PMID: 26092640.26092640
7 Myers SM, Johnson CP. Management of children with autism spectrum disorders. Pediatrics. 2007 Nov;120(5):1162–82. doi: peds.2007-2362 [pii] 10.1542/peds.2007-2362 [doi]. PMID: 17967921.17967921
8 National Autism Center. National Standards Report National Autism Center. Randolph, MA: National Autism Center; 2009. Available from http://www.nationalautismcenter.org/pdf/NAC%20Standards%20Report.pdf
9 National Research Council. Committee on Educational Interventions for Children with Autism. Educating Children with Autism Washington DC: National Academies Press; 2001. Available from http://www.nap.edu/openbook.php?record_id=10017&page=R2
10 US Food and Drug Administration. Beware of False or Misleading Claims for Treating Autism. Available from http://www.fda.gov/ForConsumers/ConsumerUpdates/ucm394757.htm.
11 Warren Z, Veenstra-VanderWeele J, Stone W, Bruzek JL, Nahmias AS, Foss-Feig JH, Jerome RN, Krishnaswami S, Sathe NA, Glasser AM, Surawicz T, McPheeters ML. Therapies for Children With Autism Spectrum Disorders. Comparative Effectiveness Review No. 26. (Prepared by the Vanderbilt Evidence-based Practice Center under Contract No. 290-2007-10065-I.) AHRQ Publication No. 11-EHC029-EF. Rockville, MD: Agency for Healthcare Research and Quality. April 2011. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm.
12 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality. January 2014. Chapters available at: www.effectivehealthcare.ahrq.gov
13 Weitlauf AS, McPheeters ML, Peters B, Sathe N, Travis R, Aiello R, Williamson E, Veenstra-VanderWeele J, Krishnaswami S, Jerome R, Warren Z. Therapies for Children With Autism Spectrum Disorder: Behavioral Interventions Update. Comparative Effectiveness Review No. 137. (Prepared by the Vanderbilt Evidence-based Practice Center under Contract No. 290-2012-00009-I.) AHRQ Publication No. 14-EHC036-EF. Rockville, MD: Agency for Healthcare Research and Quality; August 2014. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
14 Berkman ND, Lohr KN, Ansari M, McDonagh M, Balk E, Whitlock E, Reston J, Bass E, Butler M, Gartlehner G, Hartling L, Kane R, McPheeters M, Morgan L, Morton SC, Sista P, Viswanathan M, Chang S. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update RTI-UNC Evidence-based Practice Center, Contract No. HHSA-290-2007-10056-I-EPC3, Task Order #5.
15 Marcus RN, Owen R, Manos G, . Aripiprazole in the treatment of irritability in pediatric patients (aged 6–17 years) with autistic disorder: results from a 52-week, open-label study. J Child Adolesc Psychopharmacol. 2011 Jun;21(3):229–36. doi: 10.1089/cap.2009.0121. PMID: 21663425.21663425
16 Aman MG, Kasper W, Manos G, . Line-item analysis of the Aberrant Behavior Checklist: results from two studies of aripiprazole in the treatment of irritability associated with autistic disorder. J Child Adolesc Psychopharmacol. 2010 Oct;20(5):415–22. doi: 10.1089/cap.2009.0120. PMID: 20973712.20973712
17 Varni JW, Handen BL, Corey-Lisle PK, . Effect of aripiprazole 2 to 15 mg/d on health-related quality of life in the treatment of irritability associated with autistic disorder in children: a post hoc analysis of two controlled trials. Clin Ther. 2012 Apr;34(4):980–92. doi: 10.1016/j.clinthera.2012.02.023. PMID: 22444782.22444782
18 Marcus RN, Owen R, Manos G, . Safety and tolerability of aripiprazole for irritability in pediatric patients with autistic disorder: a 52-week, open-label, multicenter study. J Clin Psychiatry. 2011 Sep;72(9):1270–6. doi: 10.4088/JCP.09m05933. PMID: 21813076.21813076
19 Robb AS, Andersson C, Bellocchio EE, . Safety and tolerability of aripiprazole in the treatment of irritability associated with autistic disorder in pediatric subjects (6–17 years old):results from a pooled analysis of 2 studies. Prim Care Companion CNS Disord 2011;13(1)doi:10.4088/PCC.10m01008gry. PMID: 21731831.21731831
20 Marcus RN, Owen R, Kamen L, . A placebo-controlled, fixed-dose study of aripiprazole in children and adolescents with irritability associated with autistic disorder. J Am Acad Child Adolesc Psychiatry. 2009 Nov;48(11):1110–9. doi: 10.1097/CHI.0b013e3181b76658 [doi]. PMID: 19797985.19797985
21 Owen R, Sikich L, Marcus RN, . Aripiprazole in the treatment of irritability in children and adolescents with autistic disorder. Pediatrics. 2009 Dec;124(6):1533–40. doi: 124/6/1533 [pii] 10.1542/peds.2008-3782 [doi]. PMID: 19948625.19948625
22 King BH, Dukes K, Donnelly CL, . Baseline factors predicting placebo response to treatment in children and adolescents with autism spectrum disorders: a multisite randomized clinical trial. JAMA Pediatr. 2013 Nov;167(11):1045–52. doi: 10.1001/jamapediatrics.2013.2698. PMID: 24061784.24061784
23 King BH, Hollander E, Sikich L, . Lack of efficacy of citalopram in children with autism spectrum disorders and high levels of repetitive behavior: citalopram ineffective in children with autism. Arch Gen Psychiatry. 2009 Jun;66(6):583–90. doi: 10.1001/archgenpsychiatry.2009.30. PMID: 19487623.19487623
24 McCracken JT, Badashova KK, Posey DJ, . Positive effects of methylphenidate on hyperactivity are moderated by monoaminergic gene variants in children with autism spectrum disorders. Pharmacogenomics J. 2014 Jun;14(3):295–302. doi: 10.1038/tpj.2013.23. PMID: 23856854.23856854
25 Posey DJ, Aman MG, McCracken JT, . Positive effects of methylphenidate on inattention and hyperactivity in pervasive developmental disorders: an analysis of secondary measures. Biol Psychiatry. 2007 Feb 15;61(4):538–44. doi: S0006-3223(06)01215-7 [pii] 10.1016/j.biopsych.2006.09.028 [doi]. PMID: 17276750.17276750
26 Jahromi LB, Kasari CL, McCracken JT, . Positive Effects of Methylphenidate on Social Communication and Self-Regulation in Children with Pervasive Developmental Disorders and Hyperactivity. Journal of Autism and Developmental Disorders. 2009 Mar;39(3):395–404. PMID: EJ827753.18752063
27 Randomized, controlled, crossover trial of methylphenidate in pervasive developmental disorders with hyperactivity. Arch Gen Psychiatry. 2005 Nov;62(11):1266–74. doi: 62/11/1266 [pii] 10.1001/archpsyc.62.11.1266 [doi]. PMID: 16275814.16275814
28 Aman M, Rettiganti M, Nagaraja HN, . Tolerability, Safety, and Benefits of Risperidone in Children and Adolescents with Autism: 21-Month Follow-up After 8-Week Placebo-Controlled Trial. J Child Adolesc Psychopharmacol. 2015 Aug;25(6):482–93. doi: 10.1089/cap.2015.0005. PMID: 26262903.26262903
29 Arnold LE, Farmer C, Kraemer HC, . Moderators, mediators, and other predictors of risperidone response in children with autistic disorder and irritability. J Child Adolesc Psychopharmacol. 2010 Apr;20(2):83–93. doi: 10.1089/cap.2009.0022. PMID: 20415603.20415603
30 Aman MG, Hollway JA, McDougle CJ, . Cognitive effects of risperidone in children with autism and irritable behavior. J Child Adolesc Psychopharmacol. 2008 Jun;18(3):227–36. doi: 10.1089/cap.2007.0133 [doi]. PMID: 18582177.18582177
31 Aman MG, Arnold LE, McDougle CJ, . Acute and long-term safety and tolerability of risperidone in children with autism. J Child Adolesc Psychopharmacol. 2005 Dec;15(6):869–84. doi: 10.1089/cap.2005.15.869 [doi]. PMID: 16379507.16379507
32 McDougle CJ, Scahill L, Aman MG, . Risperidone for the core symptom domains of autism: results from the study by the autism network of the research units on pediatric psychopharmacology. Am J Psychiatry. 2005 Jun;162(6):1142–8. doi: 162/6/1142 [pii] 10.1176/appi.ajp.162.6.1142 [doi]. PMID: 15930063.15930063
33 Martin A, Scahill L, Anderson GM, . Weight and leptin changes among risperidone-treated youths with autism: 6-month prospective data. Am J Psychiatry. 2004 Jun;161(6):1125–7. PMID: 15169706.15169706
34 McCracken JT, McGough J, Shah B, . Risperidone in children with autism and serious behavioral problems. N Engl J Med. 2002 Aug 1;347(5):314–21. doi: 10.1056/NEJMoa013171 [doi] 347/5/314 [pii]. PMID: 12151468.12151468
35 Arnold LE, Vitiello B, McDougle C, . Parent-defined target symptoms respond to risperidone in RUPP autism study: customer approach to clinical trials. J Am Acad Child Adolesc Psychiatry. 2003 Dec;42(12):1443–50. doi: 10.1097/01.chi.0000091946.28938.54 [doi]. PMID: 14627879.14627879
36 Risperidone treatment of autistic disorder: longer-term benefits and blinded discontinuation after 6 months. Am J Psychiatry. 2005 Jul;162(7):1361–9. doi: 162/7/1361 [pii] 10.1176/appi.ajp.162.7.1361 [doi]. PMID: 15994720.15994720
37 Williams SK, Scahill L, Vitiello B, . Risperidone and adaptive behavior in children with autism. J Am Acad Child Adolesc Psychiatry. 2006 Apr;45(4):431–9. doi: 10.1097/01.chi.0000196423.80717.32 [doi] 00004583-200604000-00010 [pii]. PMID: 16601648.16601648
38 Scahill L, Sukhodolsky DG, Anderberg E, . Sensitivity of the modified Children’s Yale-Brown Obsessive Compulsive Scale to detect change: Results from two multi-site trials. Autism. 2015 Apr 16doi: 10.1177/1362361315574889. PMID: 25882391.25882391
39 Scahill L, Hallett V, Aman MG, . Brief Report: social disability in autism spectrum disorder: results from Research Units on Pediatric Psychopharmacology (RUPP) Autism Network trials. J Autism Dev Disord. 2013 Mar;43(3):739–46. doi: 10.1007/s10803-012-1689-3. PMID: 23104617.23104617
40 Arnold LE, Aman MG, Cook AM, . Atomoxetine for hyperactivity in autism spectrum disorders: placebo-controlled crossover pilot trial. J Am Acad Child Adolesc Psychiatry. 2006 Oct;45(10):1196–205. doi: 10.1097/01.chi.0000231976.28719.2a [doi] 00004583-200610000-00007 [pii]. PMID: 17003665.17003665
41 van der Meer JM, Harfterkamp M, van de Loo-Neus G, . A randomized, double-blind comparison of atomoxetine and placebo on response inhibition and interference control in children and adolescents with autism spectrum disorder and comorbid attention-deficit/hyperactivity disorder symptoms. J Clin Psychopharmacol. 2013 Dec;33(6):824–7. doi: 10.1097/JCP.0b013e31829c764f. PMID: 24018545.24018545
42 Harfterkamp M, Buitelaar JK, Minderaa RB, . Atomoxetine in autism spectrum disorder: no effects on social functioning; some beneficial effects on stereotyped behaviors, inappropriate speech, and fear of change. J Child Adolesc Psychopharmacol. 2014 Nov;24(9):481–5. doi: 10.1089/cap.2014.0026. PMID: 25369243.25369243
43 Harfterkamp M, van de Loo-Neus G, Minderaa RB, . A randomized double-blind study of atomoxetine versus placebo for attention-deficit/hyperactivity disorder symptoms in children with autism spectrum disorder. J Am Acad Child Adolesc Psychiatry. 2012 Jul;51(7):733–41. doi: 10.1016/j.jaac.2012.04.011. PMID: 22721596.22721596
44 Harfterkamp M, Buitelaar JK, Minderaa RB, . Long-term treatment with atomoxetine for attention-deficit/hyperactivity disorder symptoms in children and adolescents with autism spectrum disorder: an open-label extension study. J Child Adolesc Psychopharmacol. 2013 Apr;23(3):194–9. doi: 10.1089/cap.2012.0012. PMID: 23578015.23578015
45 Pearson DA, Santos CW, Aman MG, . Effects of extended release methylphenidate treatment on ratings of attention-deficit/hyperactivity disorder (ADHD) and associated behavior in children with autism spectrum disorders and ADHD symptoms. J Child Adolesc Psychopharmacol. 2013 Jun;23(5):337–51. doi: 10.1089/cap.2012.0096. PMID: 23782128.23782128
46 Scahill L, McCracken JT, King BH, . Extended-Release Guanfacine for Hyperactivity in Children With Autism Spectrum Disorder. Am J Psychiatry. 2015 Aug 28:appiajp201515010055. doi: 10.1176/appi.ajp.2015.15010055. PMID: 26315981.26315981
47 Nikvarz N, Alaghband-Rad J, Tehrani-Doost M, . Comparing Efficacy and Side Effects of Memantine vs. Risperidone in the Treatment of Autistic Disorder. Pharmacopsychiatry. 2016 Jun 14doi: 10.1055/s-0042-108449. PMID: 27299475.27299475
48 Findling RL, Mankoski R, Timko K, . A randomized controlled trial investigating the safety and efficacy of aripiprazole in the long-term maintenance treatment of pediatric patients with irritability associated with autistic disorder. J Clin Psychiatry. 2014 Jan;75(1):22–30. doi: 10.4088/JCP.13m08500 10.4088/JCP.13m8500. PMID: 24502859.24502859
49 Ghanizadeh A, Sahraeizadeh A, Berk M. A head-to-head comparison of aripiprazole and risperidone for safety and treating autistic disorders, a randomized double blind clinical trial. Child Psychiatry Hum Dev. 2014;45(2):185–92. doi: 10.1007/s10578-013-0390-x. PMID: 23801256.23801256
50 Lamberti M, Siracusano R, Italiano D, . Head-to-Head Comparison of Aripiprazole and Risperidone in the Treatment of ADHD Symptoms in Children with Autistic Spectrum Disorder and ADHD: A Pilot, Open-Label, Randomized Controlled Study. Paediatr Drugs. 2016 Aug;18(4):319–29. doi: 10.1007/s40272-016-0183-3. PMID: 27278054.27278054
51 Kent JM, Kushner S, Ning X, . Risperidone dosing in children and adolescents with autistic disorder: a double-blind, placebo-controlled study. J Autism Dev Disord. 2013 Aug;43(8):1773–83. doi: 10.1007/s10803-012-1723-5. PMID: 23212807.23212807
52 Kent JM, Hough D, Singh J, . An open-label extension study of the safety and efficacy of risperidone in children and adolescents with autistic disorder. J Child Adolesc Psychopharmacol. 2013 Dec;23(10):676–86. doi: 10.1089/cap.2012.0058. PMID: 24350813.24350813
53 Klaiman C, Huffman L, Masaki L, . Tetrahydrobiopterin as a treatment for autism spectrum disorders: a double-blind, placebo-controlled trial. J Child Adolesc Psychopharmacol. 2013 Jun;23(5):320–8. doi: 10.1089/cap.2012.0127. PMID: 23782126.23782126
54 Handen BL, Aman MG, Arnold LE, . Atomoxetine, Parent Training, and Their Combination in Children With Autism Spectrum Disorder and Attention-Deficit/Hyperactivity Disorder. J Am Acad Child Adolesc Psychiatry. 2015 Nov;54(11):905–15. doi: 10.1016/j.jaac.2015.08.013. PMID: 26506581.26506581
55 Smith T, Aman MG, Arnold LE, . Atomoxetine and Parent Training for Children With Autism and Attention-Deficit/Hyperactivity Disorder: A 24-Week Extension Study. J Am Acad Child Adolesc Psychiatry. 2016 Oct;55(10):868–76.e2. doi: 10.1016/j.jaac.2016.06.015. PMID: 27663942.27663942
56 Du L, Shan L, Wang B, . A Pilot Study on the Combination of Applied Behavior Analysis and Bumetanide Treatment for Children with Autism. J Child Adolesc Psychopharmacol. 2015 Sep;25(7):585–8. doi: 10.1089/cap.2015.0045. PMID: 26258842.26258842
57 Cortesi F, Giannotti F, Sebastiani T, . Controlled-release melatonin, singly and combined with cognitive behavioural therapy, for persistent insomnia in children with autism spectrum disorders: a randomized placebo-controlled trial. J Sleep Res. 2012 Dec;21(6):700–9. doi: 10.1111/j.1365-2869.2012.01021.x. PMID: 22616853.22616853
58 Navarro F, Pearson DA, Fatheree N, . Are ‘leaky gut’ and behavior associated with gluten and dairy containing diet in children with autism spectrum disorders? Nutr Neurosci. 2015 May;18(4):177–85. doi: 10.1179/1476830514y.0000000110. PMID: 24564346.24564346
59 Pusponegoro HD, Ismael S, Firmansyah A, . Gluten and casein supplementation does not increase symptoms in children with autism spectrum disorder. Acta Paediatr. 2015 Nov;104(11):e500–e5. doi: 10.1111/apa.13108. PMID: 26148018.26148018
60 Hyman SL, Stewart PA, Foley J, . The Gluten-Free/Casein-Free Diet: A Double-Blind Challenge Trial in Children with Autism. J Autism Dev Disord. 2015 Sep 5doi: 10.1007/s10803-015-2564-9. PMID: 26343026.26343026
61 Al-Ayadhi LY, Elamin NE. Camel Milk as a Potential Therapy as an Antioxidant in Autism Spectrum Disorder (ASD). Evid Based Complement Alternat Med. 2013;2013:602834. doi: 10.1155/2013/602834. PMID: 24069051.24069051
62 Ghalichi F, Ghaemmaghami J, Malek A, . Effect of gluten free diet on gastrointestinal and behavioral indices for children with autism spectrum disorders: a randomized clinical trial. World J Pediatr. 2016 Jun 10doi: 10.1007/s12519-016-0040-z. PMID: 27286693.27286693
63 Johnson CR, Handen BL, Zimmer M, . Effects of gluten free/casein free diet in young children with autism: A pilot study. Journal of Developmental and Physical Disabilities 2011 2015-12-09;23(3):213–25. doi: http://dx.doi.org/10.1007/s10882-010-9217-x. PMID: 888750170; 2011-08445-004.
64 Whiteley P, Haracopos D, Knivsberg AM, . The ScanBrit randomised, controlled, single-blind study of a gluten- and casein-free dietary intervention for children with autism spectrum disorders. Nutr Neurosci. 2010 Apr;13(2):87–100. doi: 10.1179/147683010x12611460763922. PMID: 20406576.20406576
65 Pedersen L, Parlar S, Kvist K, . Data mining the ScanBrit study of a gluten- and casein-free dietary intervention for children with autism spectrum disorders: behavioural and psychometric measures of dietary response. Nutr Neurosci. 2014 Sep;17(5):207–13. doi: 10.1179/1476830513y.0000000082. PMID: 24075141.24075141
66 Sampanthavivat M, Singkhwa W, Chaiyakul T, . Hyperbaric oxygen in the treatment of childhood autism: a randomised controlled trial. Diving Hyperb Med. 2012 Sep;42(3):128–33. PMID: 22987458.22987458
67 Granpeesheh D, Tarbox J, Dixon DR, . Randomized trial of hyperbaric oxygen therapy for children with autism. Research in Autism Spectrum Disorders. 2010 April 2010/June;4(2):268–75. doi: http://dx.doi.org/10.1016/j.rasd.2009.09.014. PMID: 2010025300.
68 Wright B, Sims D, Smart S, . Melatonin versus placebo in children with autism spectrum conditions and severe sleep problems not amenable to behaviour management strategies: a randomised controlled crossover trial. J Autism Dev Disord. 2011 Feb;41(2):175–84. doi: 10.1007/s10803-010-1036-5. PMID: 20535539.20535539
69 Amatachaya A, Jensen MP, Patjanasoontorn N, . The short-term effects of transcranial direct current stimulation on electroencephalography in children with autism: a randomized crossover controlled trial. Behav Neurol. 2015;2015:928631. doi: 10.1155/2015/928631. PMID: 25861158.25861158
70 Amatachaya A, Auvichayapat N, Patjanasoontorn N, . Effect of anodal transcranial direct current stimulation on autism: a randomized double-blind crossover trial. Behav Neurol. 2014;2014:173073. doi: 10.1155/2014/173073. PMID: 25530675.25530675
71 Dadds MR, MacDonald E, Cauchi A, . Nasal oxytocin for social deficits in childhood autism: a randomized controlled trial. J Autism Dev Disord. 2014 Mar;44(3):521–31. doi: 10.1007/s10803-013-1899-3. PMID: 23888359.23888359
72 Lemonnier E, Degrez C, Phelep M, . A randomised controlled trial of bumetanide in the treatment of autism in children. Transl Psychiatry. 2012;2:e202. doi: 10.1038/tp.2012.124. PMID: 23233021.23233021
73 Arnold LE, Aman MG, Hollway J, . Placebo-controlled pilot trial of mecamylamine for treatment of autism spectrum disorders. J Child Adolesc Psychopharmacol. 2012 Jun;22(3):198–205. doi: 10.1089/cap.2011.0056. PMID: 22537359.22537359
74 Hollander E, Chaplin W, Soorya L, . Divalproex sodium vs placebo for the treatment of irritability in children and adolescents with autism spectrum disorders. Neuropsychopharmacology. 2010 Mar;35(4):990–8. doi: 10.1038/npp.2009.202. PMID: 20010551.20010551
75 Aman MG, Findling RL, Hardan AY, . Safety and Efficacy of Memantine in Children with Autism: Randomized, Placebo-Controlled Study and Open-Label Extension. J Child Adolesc Psychopharmacol. 2016 Mar 15doi: 10.1089/cap.2015.0146. PMID: 26978327.26978327
76 Chugani DC, Chugani HT, Wiznitzer M, . Efficacy of Low-Dose Buspirone for Restricted and Repetitive Behavior in Young Children with Autism Spectrum Disorder: A Randomized Trial. J Pediatr. 2016 Mar;170:45–53.e1–4. doi: 10.1016/j.jpeds.2015.11.033. PMID: 26746121.26746121
77 Handen BL, Johnson CR, McAuliffe-Bellin S, . Safety and efficacy of donepezil in children and adolescents with autism: neuropsychological measures. J Child Adolesc Psychopharmacol. 2011 Feb;21(1):43–50. doi: 10.1089/cap.2010.0024. PMID: 21309696.21309696
78 Hardan AY, Fung LK, Libove RA, . A randomized controlled pilot trial of oral N-acetylcysteine in children with autism. Biol Psychiatry. 2012 Jun 1;71(11):956–61. doi: 10.1016/j.biopsych.2012.01.014. PMID: 22342106.22342106
79 Dean OM, Gray KM, Villagonzalo KA, . A randomised, double blind, placebo-controlled trial of a fixed dose of N-acetyl cysteine in children with autistic disorder. Aust N Z J Psychiatry. 2016 Jun 17doi: 10.1177/0004867416652735. PMID: 27316706.27316706
80 Bent S, Hendren RL, Zandi T, . Internet-based, randomized, controlled trial of omega-3 fatty acids for hyperactivity in autism. J Am Acad Child Adolesc Psychiatry. 2014 Jun;53(6):658–66. doi: 10.1016/j.jaac.2014.01.018. PMID: 24839884.24839884
81 Bent S, Bertoglio K, Ashwood P, . A pilot randomized controlled trial of omega-3 fatty acids for autism spectrum disorder. J Autism Dev Disord. 2011 May;41(5):545–54. doi: 10.1007/s10803-010-1078-8. PMID: 20683766.20683766
82 Voigt RG, Mellon MW, Katusic SK, . Dietary docosahexaenoic acid supplementation in children with autism. J Pediatr Gastroenterol Nutr. 2014 Jun;58(6):715–22. doi: 10.1097/mpg.0000000000000260. PMID: 24345834.24345834
83 Bertoglio K, Jill James S, Deprey L, . Pilot study of the effect of methyl B12 treatment on behavioral and biomarker measures in children with autism. J Altern Complement Med. 2010 May;16(5):555–60. doi: 10.1089/acm.2009.0177. PMID: 20804367.20804367
84 Mankad D, Dupuis A, Smile S, . A randomized, placebo controlled trial of omega-3 fatty acids in the treatment of young children with autism. Mol Autism. 2015;6:18. doi: 10.1186/s13229-015-0010-7. PMID: 25798215.25798215
85 Saad K, Eltayeb AA, Mohamad IL, . A Randomized, Placebo-controlled Trial of Digestive Enzymes in Children with Autism Spectrum Disorders. Clin Psychopharmacol Neurosci. 2015 Aug 31;13(2):188–93. doi: 10.9758/cpn.2015.13.2.188. PMID: 26243847.26243847
86 Fahmy SF, El-hamamsy MH, Zaki OK, . L-Carnitine supplementation improves the behavioral symptoms in autistic children. Research in Autism Spectrum Disorders. 2013;7(1):159–66. doi: http://dx.doi.org/10.1016/j.rasd.2012.07.006. PMID: 1267033812; 2012-29769-018.
87 Hendren RL, James SJ, Widjaja F, . Randomized, Placebo-Controlled Trial of Methyl B12 for Children with Autism. J Child Adolesc Psychopharmacol. 2016 Feb 18doi: 10.1089/cap.2015.0159. PMID: 26889605.26889605
88 Geier DA, Kern JK, Davis G, . A prospective double-blind, randomized clinical trial of levocarnitine to treat autism spectrum disorders. Med Sci Monit. 2011 Jun;17(6):Pi15–23. PMID: 21629200.21629200
89 Ghaleiha A, Alikhani R, Kazemi MR, . Minocycline as Adjunctive Treatment to Risperidone in Children with Autistic Disorder: A Randomized, Double-Blind Placebo-Controlled Trial. J Child Adolesc Psychopharmacol. 2016 Apr 29doi: 10.1089/cap.2015.0175. PMID: 27128958.27128958
90 Nikoo M, Radnia H, Farokhnia M, . N-acetylcysteine as an adjunctive therapy to risperidone for treatment of irritability in autism: a randomized, double-blind, placebo-controlled clinical trial of efficacy and safety. Clin Neuropharmacol. 2015 Jan–Feb;38(1):11–7. doi: 10.1097/wnf.0000000000000063. PMID: 25580916.25580916
91 Ghaleiha A, Mohammadi E, Mohammadi MR, . Riluzole as an adjunctive therapy to risperidone for the treatment of irritability in children with autistic disorder: a double-blind, placebo-controlled, randomized trial. Paediatr Drugs. 2013 Dec;15(6):505–14. doi: 10.1007/s40272-013-0036-2. PMID: 23821414.23821414
92 Ghanizadeh A, Ayoobzadehshirazi A. A randomized double-blind placebo-controlled clinical trial of adjuvant buspirone for irritability in autism. Pediatr Neurol. 2015 Jan;52(1):77–81. doi: 10.1016/j.pediatrneurol.2014.09.017. PMID: 25451017.25451017
93 Ghanizadeh A, Moghimi-Sarani E. A randomized double blind placebo controlled clinical trial of N-Acetylcysteine added to risperidone for treating autistic disorders. BMC Psychiatry. 2013;13:196. doi: 10.1186/1471-244x-13-196. PMID: 23886027.23886027
94 Asadabadi M, Mohammadi MR, Ghanizadeh A, . Celecoxib as adjunctive treatment to risperidone in children with autistic disorder: a randomized, double-blind, placebo-controlled trial. Psychopharmacology (Berl). 2013 Jan;225(1):51–9. doi: 10.1007/s00213-012-2796-8. PMID: 22782459.22782459
95 Ghaleiha A, Asadabadi M, Mohammadi MR, . Memantine as adjunctive treatment to risperidone in children with autistic disorder: a randomized, double-blind, placebo-controlled trial. Int J Neuropsychopharmacol. 2013 May;16(4):783–9. doi: 10.1017/s1461145712000880. PMID: 22999292.22999292
96 Mohammadi MR, Yadegari N, Hassanzadeh E, . Double-blind, placebo-controlled trial of risperidone plus amantadine in children with autism: a 10-week randomized study. Clin Neuropharmacol. 2013 Nov–Dec;36(6):179–84. doi: 10.1097/WNF.0b013e3182a9339d. PMID: 24201232.24201232
97 Hasanzadeh E, Mohammadi MR, Ghanizadeh A, . A double-blind placebo controlled trial of Ginkgo biloba added to risperidone in patients with autistic disorders. Child Psychiatry Hum Dev. 2012 Oct;43(5):674–82. doi: 10.1007/s10578-012-0292-3. PMID: 22392415.22392415
98 Rezaei V, Mohammadi MR, Ghanizadeh A, . Double-blind, placebo-controlled trial of risperidone plus topiramate in children with autistic disorder. Prog Neuropsychopharmacol Biol Psychiatry. 2010 Oct 1;34(7):1269–72. doi: 10.1016/j.pnpbp.2010.07.005. PMID: 20637249.20637249
99 Ghaleiha A, Rasa SM, Nikoo M, . A pilot double-blind placebo-controlled trial of pioglitazone as adjunctive treatment to risperidone: Effects on aberrant behavior in children with autism. Psychiatry Res. 2015 Sep 30;229(1–2):181–7. doi: 10.1016/j.psychres.2015.07.043. PMID: 26208985.26208985
100 Ghaleiha A, Ghyasvand M, Mohammadi MR, . Galantamine efficacy and tolerability as an augmentative therapy in autistic children: A randomized, double-blind, placebo-controlled trial. J Psychopharmacol. 2013 Oct 15;28(7):677–85. doi: 10.1177/0269881113508830. PMID: 24132248.24132248
101 Miral S, Gencer O, Inal-Emiroglu FN, . Risperidone versus haloperidol in children and adolescents with AD : a randomized, controlled, double-blind trial. Eur Child Adolesc Psychiatry. 2008 Feb;17(1):1–8. doi: 10.1007/s00787-007-0620-5 [doi]. PMID: 18080171.18080171
102 Troost PW, Lahuis BE, Steenhuis MP, . Long-term effects of risperidone in children with autism spectrum disorders: a placebo discontinuation study. J Am Acad Child Adolesc Psychiatry. 2005 Nov;44(11):1137–44. doi: 00004583-200511000-00009 [pii]. PMID: 16239862.16239862
103 Danfors T, von Knorring AL, Hartvig P, . Tetrahydrobiopterin in the treatment of children with autistic disorder: a double-blind placebo-controlled crossover study. J Clin Psychopharmacol. 2005 Oct;25(5):485–9. doi: 00004714-200510000-00015 [pii]. PMID: 16160627.16160627
104 Knivsberg AM, Reichelt KL, Hoien T, . A randomised, controlled study of dietary intervention in autistic syndromes. Nutr Neurosci. 2002 Sep;5(4):251–61. PMID: 12168688.12168688
105 Knivsberg A-M, Reichelt K-L, Høien T, . Effect of a Dietary Intervention on Autistic Behavior. Focus on Autism and Other Developmental Disabilities. 2003 Win;18(4):247–56.
106 Harrison Elder J, Shankar M, Shuster J, . The Gluten-Free, Casein-Free Diet In Autism: Results of A Preliminary Double Blind Clinical Trial. Journal of Autism and Developmental Disorders. 2006 Apr;36(3):413–20. PMID: 2006-07517-011.16555138
107 Seung H, Rogalski Y, Shankar M, . The gluten- and casein-free diet and autism: Communication outcomes from a preliminary double-blind clinical trial. Journal of Medical Speech-Language Pathology. 2007 Dec;15(4):337–45.
108 Wasserman S, Iyengar R, Chaplin WF, . Levetiracetam versus placebo in childhood and adolescent autism: a double-blind placebo-controlled study. Int Clin Psychopharmacol. 2006 Nov;21(6):363–7. doi: 10.1097/01.yic.0000224787.13782.0f [doi] 00004850-200611000-00006 [pii]. PMID: 17012983.17012983
109 Nagaraj R, Singhi P, Malhi P. Risperidone in children with autism: randomized, placebo-controlled, double-blind study. J Child Neurol. 2006 Jun;21(6):450–5. PMID: 16948927.16948927
110 Levine SZ, Kodesh A, Goldberg Y, . Initial severity and efficacy of risperidone in autism: Results from the RUPP trial. Eur Psychiatry. 2016 Feb;32:16–20. doi: 10.1016/j.eurpsy.2015.11.004. PMID: 26802979.26802979
111 Anderson GM, Scahill L, McCracken JT, . Effects of short- and long-term risperidone treatment on prolactin levels in children with autism. Biol Psychiatry. 2007 Feb 15;61(4):545–50. doi: S0006-3223(06)00384-2 [pii] 10.1016/j.biopsych.2006.02.032 [doi]. PMID: 16730335.16730335
112 Shea S, Turgay A, Carroll A, . Risperidone in the treatment of disruptive behavioral symptoms in children with autistic and other pervasive developmental disorders. Pediatrics. 2004 Nov;114(5):e634–41. doi: peds.2003-0264-F [pii] 10.1542/peds.2003-0264-F [doi]. PMID: 15492353.15492353
113 Pandina GJ, Bossie CA, Youssef E, . Risperidone improves behavioral symptoms in children with autism in a randomized, double-blind, placebo-controlled trial. J Autism Dev Disord. 2007 Feb;37(2):367–73. doi: 10.1007/s10803-006-0234-7 [doi]. PMID: 17019624.17019624
114 Rossignol DA, Rossignol LW, Smith S, . Hyperbaric treatment for children with autism: a multicenter, randomized, double-blind, controlled trial. BMC Pediatr. 2009;9:21. doi: 1471-2431-9-21 [pii] 10.1186/1471-2431-9-21 [doi]. PMID: 19284641.19284641
115 King BH, Wright DM, Handen BL, . Double-blind, placebo-controlled study of amantadine hydrochloride in the treatment of children with autistic disorder. J Am Acad Child Adolesc Psychiatry. 2001 Jun;40(6):658–65. PMID: 11392343.11392343
116 Chez MG, Buchanan TM, Becker M, . Donepezil hydrochloride: A double-blind study in autistic children. Journal of Pediatric Neurology. 2003 Oct–Dec;1(2):83–8. PMID: 2004-12732-002.
117 Munasinghe SA, Oliff C, Finn J, . Digestive enzyme supplementation for autism spectrum disorders: a double-blind randomized controlled trial. J Autism Dev Disord. 2010 Sep;40(9):1131–8. doi: 10.1007/s10803-010-0974-2. PMID: 20204691.20204691
118 Akhondzadeh S, Fallah J, Mohammadi MR, . Double-blind placebo-controlled trial of pentoxifylline added to risperidone: effects on aberrant behavior in children with autism. Prog Neuropsychopharmacol Biol Psychiatry. 2010 Feb 1;34(1):32–6. doi: 10.1016/j.pnpbp.2009.09.012. PMID: 19772883.19772883
119 Selim ME, Al-Ayadhi LY. Possible ameliorative effect of breastfeeding and the uptake of human colostrum against coeliac disease in autistic rats. World J Gastroenterol. 2013 Jun 7;19(21):3281–90. doi: 10.3748/wjg.v19.i21.3281. PMID: 23745030.23745030
120 Lv YT, Zhang Y, Liu M, . Transplantation of human cord blood mononuclear cells and umbilical cord-derived mesenchymal stem cells in autism. J Transl Med. 2013;11:196. doi: 10.1186/1479-5876-11-196. PMID: 23978163.23978163
121 Sun C, Zou M, Zhao D, . Efficacy of Folic Acid Supplementation in Autistic Children Participating in Structured Teaching: An Open-Label Trial. Nutrients 2016;8(6)doi: 10.3390/nu8060337. PMID: 27338456.27338456
122 Wink LK, Early M, Schaefer T, . Body mass index change in autism spectrum disorders: comparison of treatment with risperidone and aripiprazole. J Child Adolesc Psychopharmacol. 2014 Mar;24(2):78–82. doi: 10.1089/cap.2013.0099. PMID: 24564519.24564519
123 Duffy FH, Shankardass A, McAnulty GB, . Corticosteroid therapy in regressive autism: a retrospective study of effects on the Frequency Modulated Auditory Evoked Response (FMAER), language, and behavior. BMC Neurol. 2014;14:70. doi: 10.1186/1471-2377-14-70. PMID: 24885033.24885033
124 Akhondzadeh S, Tajdar H, Mohammadi MR, . A double-blind placebo controlled trial of piracetam added to risperidone in patients with autistic disorder. Child Psychiatry Hum Dev. 2008 Sep;39(3):237–45. doi: 10.1007/s10578-007-0084-3 [doi]. PMID: 17929164.17929164
125 Scarpa A, Reyes NM. Improving emotion regulation with CBT in young children with high functioning autism spectrum disorders: a pilot study. Behav Cogn Psychother. 2011 Jul;39(4):495–500. doi: 10.1017/s1352465811000063. PMID: 21457605.21457605
126 Aman MG, McDougle CJ, Scahill L, . Medication and Parent Training in Children With Pervasive Developmental Disorders and Serious Behavior Problems: Results From a Randomized Clinical Trial. J Am Acad Child Adolesc Psychiatry. 2009 Oct 23doi: 10.1097/CHI.0b013e3181bfd669 [doi]. PMID: 19858761.19858761
127 Cunningham AB. Measuring change in social interaction skills of young children with autism. J Autism Dev Disord. 2012 Apr;42(4):593–605. doi: 10.1007/s10803-011-1280-3. PMID: 21638109.21638109
128 Kern JK, Miller VS, Cauller PL, . Effectiveness of N,N-dimethylglycine in autism and pervasive developmental disorder. J Child Neurol. 2001 Mar;16(3):169–73. PMID: 11305684.11305684
129 Hong ER, Neely L, Rispoli MJ, . A comparison of general and explicit delay cues to reinforcement for tangible-maintained challenging behaviour. Dev Neurorehabil. 2015 Aug 24:1–7. doi: 10.3109/17518423.2013.874378. PMID: 24392663.24392663
130 Barnard-Brak L, Thompson S, Wei T, . Assistive technology as a predictor of general or alternate assessment among elementary-aged students with autism spectrum disorders. Assist Technol. 2014 Summer;26(2):81–7. doi: 10.1080/10400435.2013.833557. PMID: 25112052.25112052
131 Goldman S, DeNigris D. Parents’ strategies to elicit autobiographical memories in autism spectrum disorders, developmental language disorders and typically developing children. J Autism Dev Disord. 2015 May;45(5):1464–73. doi: 10.1007/s10803-014-2271-y. PMID: 25312278.25312278
132 Zeedyk SM, Cohen SR, Eisenhower A, . Perceived social competence and loneliness among young children with ASD: Child, parent and teacher reports. Journal of Autism and Developmental Disorders. 2016;46(2):436–49. doi: http://dx.doi.org/10.1007/s10803-015-2575-6.26363914
133 Ching H, Pringsheim T. Aripiprazole for autism spectrum disorders (ASD). Cochrane Database of Systematic Reviews 2012.(5)
134 Deb S, Farmah BK, Arshad E, . The effectiveness of aripiprazole in the management of problem behaviour in people with intellectual disabilities, developmental disabilities and/or autistic spectrum disorder--a systematic review. Res Dev Disabil. 2014 Mar;35(3):711–25. doi: 10.1016/j.ridd.2013.12.004. PMID: 24405794.24405794
135 Sharma A, Shaw SR. Efficacy of Risperidone in Managing Maladaptive Behaviors for Children With Autistic Spectrum Disorder: A Meta-Analysis. Journal of Pediatric Healthcare. 2012;26(4):291–9 9p. doi: 10.1016/j.pedhc.2011.02.008.
136 Fung LK, Mahajan R, Nozzolillo A, . Pharmacologic Treatment of Severe Irritability and Problem Behaviors in Autism: A Systematic Review and Meta-analysis. Pediatrics. 2016 Feb;137 Suppl 2:S124–35. doi: 10.1542/peds.2015-2851K. PMID: 26908468.26908468
137 Siegel M, Beaulieu A. Psychotropic Medications in Children with Autism Spectrum Disorders: A Systematic Review and Synthesis for Evidence-Based Practice. Journal of Autism & Developmental Disorders. 2012;42(8):1592–605 14p. doi: 10.1007/s10803-011-1399-2.22068820
138 Reichow B, Volkmar FR, Bloch MH. Systematic review and meta-analysis of pharmacological treatment of the symptoms of attention-deficit/hyperactivity disorder in children with pervasive developmental disorders. J Autism Dev Disord. 2013 Oct;43(10):2435–41. doi: 10.1007/s10803-013-1793-z. PMID: 23468071.23468071
139 Hirota T, Veenstra-VanderWeele J, Hollander E, . Antiepileptic Medications in Autism Spectrum Disorder: A Systematic Review and Meta-Analysis. Journal of Autism & Developmental Disorders. 2014;44(4):948–57 10p. doi: 10.1007/s10803-013-1952-2.24077782
140 Rossignol DA, Frye RE. The use of medications approved for Alzheimer’s disease in autism spectrum disorder: a systematic review. Front Pediatr. 2014;2:87. doi: 10.3389/fped.2014.00087. PMID: 25202686.25202686
141 Masi A, Lampit A, Glozier N, . Predictors of placebo response in pharmacological and dietary supplement treatment trials in pediatric autism spectrum disorder: a meta-analysis. Transl Psychiatry. 2015;5:e640. doi: 10.1038/tp.2015.143. PMID: 26393486.26393486
142 Ghanizadeh A. Atomoxetine for treating ADHD symptoms in autism: a systematic review. J Atten Disord. 2013 Nov;17(8):635–40. doi: 10.1177/1087054712443154. PMID: 22544388.22544388
143 Ghanizadeh A. Hyperbaric oxygen therapy for treatment of children with autism: a systematic review of randomized trials. Med Gas Res. 2012;2:13. doi: 10.1186/2045-9912-2-13. PMID: 22577817.22577817
144 Williams K, Brignell A, Randall M, . Selective serotonin reuptake inhibitors (SSRIs) for autism spectrum disorders (ASD). Cochrane Database of Systematic Reviews 2013.(8)
145 James S, Montgomery P, Williams K. Omega-3 fatty acids supplementation for autism spectrum disorders (ASD). Cochrane Database Syst Rev. 2011(11):Cd007992. doi: 10.1002/14651858.CD007992.pub2. PMID: 22071839.22071839
146 Mari-Bauset S, Zazpe I, Mari-Sanchis A, . Evidence of the gluten-free and casein-free diet in autism spectrum disorders: a systematic review. J Child Neurol. 2014 Dec;29(12):1718–27. doi: 10.1177/0883073814531330. PMID: 24789114.24789114
147 Rossignol DA, Frye RE. Melatonin in autism spectrum disorders: a systematic review and meta-analysis. Dev Med Child Neurol. 2011 Sep;53(9):783–92. doi: 10.1111/j.1469-8749.2011.03980.x. PMID: 21518346.21518346
148 James S, Stevenson SW, Silove N, . Chelation for autism spectrum disorder (ASD). Cochrane Database Syst Rev. 2015 May 11;5:Cd010766. doi: 10.1002/14651858.CD010766.pub2. PMID: 26114777.26114777