# Introduction

## Background

Autism spectrum disorder (ASD) is a neurodevelopmental disorder broadly defined by impaired social communication as well as restricted or repetitive patterns of behavior and interest. As defined by the Diagnostic and Statistical Manual of Mental Disorders, Fifth edition (DSM-5), specific features of ASD include deficits in social and emotional reciprocity (e.g., atypical social approaches, conversational impairment, atypical sharing of interests, attention, and affect); deficits in nonverbal communication (e.g., poorly integrated verbal and nonverbal communication, atypical body-language and gesture use, deficits in use and understanding of nonverbal communication), and deficits in maintaining appropriate relationships (e.g., challenges with peer interest, vulnerabilities forming friendships, difficulties adjusting behavior to suit social contexts) as well as restricted and repetitive patterns of behavior such as stereotyped speech, motor movements, or use of objects; excessive adherence to routine or insistence on sameness; intense interest patterns; and atypical sensory interests or responses. Symptoms of the disorder impair and limit everyday functioning and are thought to be evident in early childhood; although they may not be fully evident until later ages. Although not core symptoms, many children with ASD may also have significant cognitive impairment and language impairments.

The prevalence of ASD in the United States is 14.7 cases per 1,000 children living in the communities surveyed, or 1 in 68, with rate estimates varying widely by region of the country, sex, and race/ethnicity.^1^ Considerably more males (1 in 42) than females (1 in 189) are affected. For some individuals, symptoms of ASD may improve with intervention and maturation; however, core deficits typically translate into varying developmental presentations that persist throughout the lifespan.^2^

### Treatment of ASD

The manifestation and severity of symptoms of ASD differ widely, and treatments include a range of behavioral, psychosocial, educational, medical, and complementary approaches^3–6^ that vary by a child’s age and developmental status. The goals of treatment for ASD typically focus on improving core deficits in communication, social interactions, or restricted behaviors, as changing these fundamental deficits may help children develop greater functional skills and independence.^7^ Treatment frequently is complicated by symptoms or comorbidities that may warrant targeted intervention (e.g., significant challenging behavior, attention and hyperactivity concerns, depression, anxiety). There is no cure for ASD and no global consensus on which intervention is most effective.^8, 9^ Individual goals for treatment vary for different children and may include combinations of behavioral therapies, educational therapies, medical and related therapies, approaches targeting sensory issues, and allied health therapies; parents may also pursue complementary and alternative medicine therapies.

The antipsychotics risperidone (Risperdal) and aripiprazole (Abilify) have been specifically approved by the U.S. Food and Drug Administration (FDA) for treatment of the comorbid symptoms of irritability and challenging behaviors in ASD. No medications have been approved specifically to treat core ASD symptoms such as communication impairments. Many medications are used off–label to manage behavioral symptoms such as anxiety and hyperactivity. In addition, other treatments such as nutritional supplements or devices such as hyperbaric oxygen chambers have been used to treat symptoms of ASD, though neither supplements or hyperbaric oxygen have been approved by the FDA for ASD treatment.^10^

## Scope and Key Questions

### Scope of Review

This review updates findings reported in the 2011 Agency for Healthcare Research and Quality (AHRQ) review of Therapies for Children with ASD^11^ with a focus on studies of medical interventions. We defined medical interventions broadly as interventions involving the administration of external substances to the body or use of external, nonbehavioral procedures to treat symptoms of ASD, which includes pharmacologic agents, diet therapies, vitamins and supplements, chelating agents, electroconvulsive therapy, transcranial magnetic stimulation and hyperbaric oxygen, among other modalities. We used this broad definition, developed with input from our clinical experts, in order to capture the landscape of medically-related interventions used to treat children with ASD.

We focused the review on children between 2 and 12 years of age. We chose to limit the age range to this span because a) diagnosis of ASD earlier than age 2 is less established and b) adolescents likely have substantially different challenges and would warrant different interventions than children in the preschool, elementary, and middle school age groups.

We integrate syntheses of comparative studies evaluating medical interventions addressed in our 2011 review of therapies for children with ASD^11^ if they addressed an agent evaluated in a study identified for the current review. To ensure comprehensive coverage of the medical literature in the current update, we also included studies that had originally been excluded in the 2011 review because of sample size. We set a lower sample size inclusion criterion in the current update.

A companion review updating findings related to interventions targeting sensory challenges is available on the AHRQ Effective Health Care Web site.

### Key Questions

We developed Key Questions (KQs) in consultation with Key Informants and the Task Order Officer. KQs were posted for review to the AHRQ Effective Health Care Web site.

KQs were as follows:

KQ1 Among children ages 2–12 with ASD, what is the comparative effectiveness (benefits and harms) of medical treatments?
  a. What are the effects on core symptoms (e.g., deficits in social communication and interaction; restricted, repetitive patterns of behavior, interests, or activities including hyper- or hypo- reactivity to sensory input or unusual interest in sensory aspects of the environment) in the short term (<6 months)?
  b. What are the effects on commonly associated symptoms (e.g., motor, medical, mood/anxiety, irritability, and hyperactivity) in the short term (<6 months)?
  c. What are the longer term effects (≥6 months) on core symptoms (e.g., social deficits, communication deficits, and repetitive behaviors)?
  d. What are the longer term effects (≥6 months) on commonly associated symptoms (e.g., motor, medical, mood/anxiety, irritability, and hyperactivity)?
KQ2 Among children ages 2–12 with ASD, what are the modifiers of outcome for different medical treatments?
  a. Is the effectiveness of the therapies reviewed affected by the frequency, duration, intensity, or dose of the intervention?
  b. Is the effectiveness of the therapies reviewed affected by co-interventions or prior treatment, or the training and/or experience of the individual providing the therapy?
  c. What characteristics (e.g., age, symptom severity), if any, of the child modify the effectiveness of the therapies reviewed?
  d. What characteristics, if any, of the family modify the effectiveness of the therapies reviewed?
KQ3 What is the time to effect of medical interventions?
KQ4 What is the evidence that effects measured at the end of the treatment phase predict long-term functional outcomes of medical interventions?
KQ5 Is the effectiveness of medical interventions maintained across environments or contexts (e.g., people, places, materials)?
KQ6 What evidence supports specific components of treatment with medical interventions as driving outcomes, either within a single treatment or across treatments?

Table 1 outlines population, intervention, comparator, outcomes, timing, and setting (PICOTS) characteristics for each KQ.

Table 1 PICOTS characteristics

PICOTS | Criteria
Population | Children with ASD between the ages of 2 and 12 years (mean age plus standard deviation is ≤ 12 years and 11 months)
Intervention(s) | Medical interventions (pharmaceutical agents, supplements and diets, hyperbaric oxygen, etc.)
Comparator | - Inactive control (e.g., no treatment, watchful waiting, waitlist control, placebo); - Alternate intervention
Outcomes | [underlined: Intermediate outcomes]; - ASD symptom severity; - Expressive or receptive language/communication; - Academic skill development; - Maladaptive behaviors; - Distress; - Adaptive skills development; - Social skills/interaction; - Harms of interventions; [underlined: Final health outcomes]; - Symptom severity or diagnostic outcome; - Functional communication; - Cognitive skills; - Motor skills; - Adaptive independence; - Academic engagement/attainment (e.g., mainstream school placement or integration); - Social participation; - Psychosocial well-being; - Psychosocial adaptation; - Harms of interventions
Timing | Any (i.e., short and long term outcomes as reported in eligible study publications)
Setting | Any primary, specialty, community, or educational setting

ASD = autism spectrum disorder; PICOTS = population, intervention, comparator, outcome, timing, setting

## Analytic Framework

The analytic framework (Figure 1) illustrates the population, interventions, outcomes, and adverse effects that guided the literature search and synthesis.

Figure 1 Analytic framework

ASD=autism spectrum disorder; KQ=Key Question

Figure 1. The analytic framework outlines the process by which families of children with ASD make and modify medical treatment choices. Treatment effectiveness may be affected by factors related to the child (e.g., age, IQ) or the context of care. Ideally, treatment effects are seen both in the short term in clinical changes and in longer term or functional outcomes. Eventual outcomes of interest include adaptive independence appropriate to the abilities of the specific child, psychological well-being, appropriate academic engagement, social participation, and psychosocial adaptation. Circled numbers represent the report’s key questions; their placement indicates the points in the treatment process in which they are likely to arise.

## Organization of This Report

The Methods section describes the review processes including search strategy, inclusion and exclusion criteria, approach to review of abstracts and full publications, methods for extraction of data, and compiling evidence. We also describe our approach to grading the risk of bias of the literature and describing the strength of the body of evidence.

The Results section presents the findings of the literature search and the review of the evidence by KQ, synthesizing the findings across strategies. We present findings for each KQ organized by intervention and outcome area. We include summary tables in the Results section for those intervention areas for which we could assess the strength of evidence for effectiveness outcomes. All other summary tables are in Appendix F. Because few studies addressed sub-questions under KQ1 and 2, we present results in the aggregate under each of these KQ.

The Discussion section of the report discusses the results and expands on methodologic considerations relevant to each KQ. We also outline the current state of the literature and challenges for future research in the field. The report includes a number of appendixes to provide further detail on our methods and the studies assessed. The appendixes are as follows:

- Appendix A: Search Strategies
- Appendix B: Screening and Risk of Bias Assessment Forms
- Appendix C: Excluded Studies
- Appendix D: Risk of Bias Ratings
- Appendix E: Applicability Summary Tables
- Appendix F: Detailed Tables of Findings

## Uses of This Evidence Report

We anticipate that the report will be of value to clinicians who treat children with ASD, who can use the report to assess the evidence for different treatment strategies. In addition, this review will be of use to the National Institutes of Health, U.S. Centers for Disease Control and Prevention, Centers for Medicare & Medicaid Services, and the Health Resources and Services Administration–all of which have offices or bureaus devoted to child health issues and who may use the report to compare treatments and determine priorities for funding. This report can bring practitioners up to date about the current state of evidence related to medical interventions, and it provides an assessment of the quality of studies that aim to determine the outcomes of medical options for the management of ASD. It will be of interest to families affected by ASD because of the recurring need for families and their health care providers to make the best possible decisions among numerous options. We also anticipate it will be of use to private sector organizations concerned with ASD; the report can inform such organizations’ understanding of the effectiveness of treatments and the amount and quality of evidence available. Researchers can obtain a concise analysis of the current state of knowledge and future research needs related to medical interventions for ASD.