# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Grace Baranek, Ph.D.
  University of North Carolina
  Chapel Hill, NC
- Daniel L. Coury, M.D.^*^
  Nationwide Children’s Hospital
  Columbus, OH
- Jennifer Frost, M.D.
  American Academy of Family Physicians
  Leawood, KS
- Susan Hyman, M.D.^*^
  University of Rochester
  Rochester, NY
- Susan Levy, M.D., M.P.H.^*^
  Children’s Hospital of Philadelphia
  Philadelphia, PA
- Jeremy Veenstra-VanderWeele, M.D.^*^
  Columbia University Medical Center
  New York, NY
- Paul Wang, M.D. ^ǂ^
  Simons Foundation
  New York, NY

* Provided input on Draft Report.

ǂ Dr. Wang was affiliated with Autism Speaks at the time he served as a Technical Expert Panel member and when he provided input on the Draft Report.