# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Ms. Jessica Kimber was an invaluable resource for assistance with data extraction and checking, and helped to locate studies and track data. Ms. Katie Worley helped to extract data and create tables. Dr. Mamata Raj assisted with screening studies and risk of bias assessment. We sincerely appreciate their dedicated work and the input of our Task Order Officers; Associate Editor, Margaret Maglione; Key Informants; and Technical Experts.