# Discussion

## State of the Literature

We identified a total of 76 unique comparative studies, primarily (n=72) randomized controlled trials (RCTs), addressing medical interventions. Most studies were small (median 40 total participants/study) and addressed variable agents. Most studies had placebo comparators, while five (reported in multiple publications) compared a pharmaceutical agent to behavioral treatment or combined pharmaceutical and behavioral treatment.^54–57, 120, 121^ Treatment length varied from four days to 24 months, with few studies (n=3) reporting longer term followup after the immediate intervention period.^71, 72, 120^

The methodologic rigor of studies increased substantially over those studies reported in our 2011 review of therapies for children with autism spectrum disorder (ASD).^11^ Thirty-three studies in the current review have low risk of bias and 20 have moderate risk. While studies were generally well-conducted, evidence remains insufficient for most interventions given small sample sizes, lack of longer term followup, and heterogeneous agents and populations.

While most studies targeted challenging behaviors, only four (reported in multiple publications) explicitly included children with diagnosed comorbidities such as attention deficit hyperactivity disorder (ADHD).^40–44, 71, 80^ Twenty-eight studies used variable criteria to define challenging behaviors, including specific cut-off scores on subscales of the Aberrant Behavior Checklist (ABC); parent-reported irritability; clinician observations of irritability or hyperactivity; or the presence of undefined “severe” behavioral symptoms. Other studies reported no specific indications.

Despite the limitations of the literature, some interventions have high strength of evidence. Specifically, the strength of evidence for the antipsychotics risperidone and aripiprazole is high for the amelioration of irritability in the short term (≤6 months of treatment) for children with significant challenging behaviors at baseline. However, the strength of evidence is also high for significant side effects (e.g., extrapyramidal symptoms, weight gain). Longer term effectiveness is not as well studied, but uncontrolled open-label analyses have suggested some continued efficacy. In studies (reported in multiple publications), children receiving the psychostimulant methylphenidate had improvements in hyperactivity, but small sample sizes preclude firm conclusions about durability of effects.^24–27, 45^ Two studies (in multiple publications) of atomoxetine also reported positive effects on hyperactivity, potentially with fewer adverse effects than methylphenidate.^40–44^ Other studies of agents such as adjuncts to risperidone reported some positive effects but studies were small, often underpowered, and typically not replicated. Studies of nutritional supplements or specialized diets reported few positive effects as did studies of hyperbaric oxygen.

Despite the number of new studies, we can make few conclusions beyond those reached in our 2011 review. Evidence supports the effectiveness of antipsychotics in improving challenging behaviors, but with significant harms. Methylphenidate also improves hyperactivity but with significant harms. Evidence is promising for the ADHD medication atomoxetine. More studies have addressed combination approaches, but data are inadequate to draw conclusions. Data were limited and inconsistent for other interventions.

## Summary of Key Findings and Strength of the Evidence

### Key Question (KQ) 1 Benefits and Harms of Medical Treatments

#### Studies of Antipsychotics

##### Key Findings

Studies of antipsychotics addressed either risperidone or aripiprazole and reported significant improvements in measures of challenging behavior in the short term (<6 months) in children receiving the medications compared with those receiving placebo. Harms of these agents, including extrapyramidal symptoms and weight gain, were also significant. Studies reporting longer term followup (up to 21 months for risperidone) suggest continued potential efficacy in many children but did not include control groups that would permit stronger conclusions. Studies comparing risperidone and aripiprazole reported few differences in effects on outcomes or harms.

##### Strength of the Evidence

Our confidence in the conclusion that risperidone and aripiprazole improve challenging behaviors in the short term (<6 months), with clinically significant harms. is high (high strength of evidence). Behaviors improved in the longer term (≥6 months) with these agents compared with placebo, but our confidence in this conclusion is low (low strength of evidence) as few studies had longer-term followup.

In studies comparing risperidone and aripiprazole, BMI increased with both drugs over treatment durations of 6 months to more than 2 years, but group differences were not significant. We have low confidence in this conclusion given the few studies addressing this outcome (low strength of evidence). Other outcomes (e.g., challenging behaviors, attention) were not consistently addressed; thus we considered strength of evidence insufficient for all other intervention/outcome pairs. Table 23 outlines these findings.

Table 23 Strength of evidence for effectiveness of antipsychotics versus placebo

Intervention/Outcome Study Design Risk of Bias and Number of Studies (N Total) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Finding Strength of Evidence Grade
Risperidone vs. placebo
Challenging behavior (≤6 months) RCT: 2 low,^34, 51, 52^ 1 moderate^112, 113^ (N=274) | Low | Consistent | Direct | Imprecise | Undetected | High SOE for short-term effectiveness of risperidone in improving challenging behavior compared with placebo Significant improvement in treatment group vs. placebo in 3 RCTs with 6–8 week treatment phases; improvement maintained in 2 RCTs with 6 months of treatment
Challenging behavior (>6 months) RCT: 2 low,^28, 102^ 1 moderate^109^ (N=118) | Low | Consistent | Direct | Imprecise | Undetected | Low SOE for effectiveness in the longer term Improvement maintained in 1 RCT with 6 months of treatment and in one open label extension with no comparison group with mean 21 months treatment duration; in another open label extension, more children relapsed with placebo vs. risperidone
Harms RCT: 5 low,^34, 49, 51, 52, 102, 130^ 4 moderate^47, 101, 109, 112, 113^ Retrospecitve cohort: 1 moderate^122^ (N=334) | Low | Consistent | Direct | Imprecise | Undetected | High SOE for clinically significant harms associated with risperidone Harms including weight gain, appetite changes, drowsiness, fatigue, extrapyramidal symptoms, drooling/hypersalivation, and gastrointestinal symptoms consistently reported
Aripiprazole vs. Placebo
Challenging behavior (≤6 months) RCT: 2 low^20, 21^ (N=316) | Low | Consistent | Direct | Precise | Undetected | High SOE for short-term effectiveness of aripiprazole in improving challenging behavior compared with placebo Significant improvements in 2 short-term RCTs in treatment groups vs. placebo
Challenging behavior (≥6 months) RCT: 2 low^15, 20, 21, 48^ (N=415) | Low | Inconsistent | Direct | Precise | Undetected | Low SOE for longer term effectiveness in improving challenging behaviors In longer term followup, no differences in time to relapse of symptoms between aripiprazole and placebo groups in one 16 week RCT and continued improvements in ABC in one 52-week open label continuation with no control arm
Harms RCT: 4 low,^18, 20, 21, 48–50^ Retrospective cohort: 1 moderate^122^ (N=492) | Low | Consistent | Direct | Precise | Undetected | High SOE for clinically significant harms associated with aripiprazole Harms including weight gain, appetite changes, somnolence, extrapyramidal symptoms, drooling/hypersalivation, infection, and gastrointestinal symptoms consistently reported
Risperidone vs. Aripirazole
BMI RCT: 1 low^50^ (N=37) Retrospective cohort: 1 moderate^122^ (N=142) | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for no difference in effects on BMI BMI increased with both drugs over treatment durations of 6 months to more than 2 years, but group differences were not significant

N = number; RCT = randomized controlled trial; SOE = strength of evidence

#### Studies of ADHD Medications

##### Key Findings

Studies of methylphenidate, atomoxetine, and guanfacine reported improvements in hyperactivity and other challenging behaviors with treatment compared with placebo. Both RCTs addressing methylphenidate reported statistically significant improvements in hyperactivity in children treated with medium to high doses compared with placebo.^24–27, 45^ Findings for oppositional behavior and social communication were inconsistent.

RCTs addressing atomoxetine reported statistically significant treatment-related improvements compared with placebo that were maintained over 20 weeks of open label, uncontrolled treatment in one study; inattention was statistically significantly improved in one study.^40–44^ One small RCT of guanfacine reported improvements in hyperactivity, impulsiveness, and attention.^46^ Side effects were associated with all agents including aggressive behavior, gastrointestinal symptoms, irritability, and appetite changes.

##### Strength of the Evidence

Methylphenidate. Methylphenidate vs. placebo improved hyperactivity and was associated with clinically significant harms (Table 24). Our confidence in these conclusions is low as studies were small and short term (low strength of evidence). Data were inadequate to assess effects on social communication and oppositional behavior (insufficient strength of evidence). Findings for oppositional behavior were inconsistent in two studies;^25, 45^ thus, we could not assess the strength of evidence (insufficient). We considered the evidence inadequate to comment on potential effects on social communication or oppositional behavior (insufficient strength of evidence).

Table 24 Strength of evidence for effects of medications to treat ADHD

Intervention/Outcome Study Design Risk of Bias and Number of Studies (N Total) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Finding Strength of Evidence Grade
Methylphenidate vs. Placebo
Hyperactivity RCT: 2 low^24–27, 45^ (N=90) | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for short-term (<6 months) improvements in hyperactivity with methylphenidate compared with placebo Significant improvement with MPH compared with placebo on parent and teacher-rated measures; differential effect of dose not clear (little effect on 1 study and linear effect in another); SOE is low given small sample size and lack of long-term followup
Harms RCT: 2 low^24–27, 45^ (N=90) | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for association of methylphenidate with clinically significant harms Rates of children experiencing harms ranged from 0–75%; higher rates reported for repetitive behaviors or speech, loss of appetite, and irritability. Irritability responsible for withdrawals (n=6) in one RCT; SOE is low given small sample size
Atomoxetine vs. Placebo
Hyperactivity RCT: 2 low, 1 moderate^40–44, 54^ (N=163) | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for improvements in hyperactivity in the short-term <6 months) with atomoxetine vs. placebo Significant improvements in rating of hyperactivity in treatment group compared with placebo in both studies
Hyperactivity RCT: 2 low ^42–44, 54, 55, 131^ (N=106) | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for improvements in hyperactivity in the longer-term ≥6 months) with atomoxetine vs. placebo Improvements in hyperactivity maintained in open label extensions
Harms RCT: 2 low, 1 moderate^40, 42–44, 54, 55, 131^ (N=241) | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for clinically moderate harms associated with atomoxetine No serious adverse events reported; most harms attenuated over open label extension phase

ADHD = attention deficit hyperactivity disorder; MPH = methylphenidate; N = number; RCT = randomized controlled trial; SOE = strength of evidence

Atomoxetine. We found positive effects of atomoxetine compared with placebo on hyperactivity in children with ASD and ADHD in the short term (<6 months), with effects maintained over the longer term (≥6 months) (Table 24). Our confidence in this conclusion is low (low strength of evidence). Atomoxetine was associated with harms considered to be clinically moderate, and our confidence in this conclusion is low (low strength of evidence). Data were inadequate to assess effects on inattention as studies reported inconsistent findings (insufficient strength of evidence).

Guanfacine. Data were inadequate in this small study to draw conclusions about effects on any outcomes (insufficient strength of evidence).

#### Studies of Combined Medical and Behavioral Treatments

##### Key Findings

Three RCTs (2 low and 1 high risk of bias) and two nonrandomized trials (1 moderate and 1 high risk of bias) addressed different medical agents in combination with behavioral approaches. Atomoxetine plus parent training or atomoxetine alone were both associated with improvements in ADHD, inattention, hyperactivity, noncompliance, and overall symptom severity compared with placebo, with improvements maintained over 24 weeks for most treatment responders in one RCT.^55, 132^ Differences between atomoxetine groups were not statistically significant for any outcome. Melatonin and melatonin plus cognitive behavioral therapy (CBT) both improved sleep-related outcomes in a second RCT.^57^

Folic acid plus Treatment and Education of Autistic and Related Communication Handicapped Children (TEACCH) treatment and folic acid alone both improved behaviors, with no significant group differences in one nonrandomized trial.^121^ In another RCT, bumetanide plus applied behavior analysis improved symptom severity and behavior more than applied behavior analysis alone.^56^ In a final nonrandomized trial, stem cell transplantation plus rehabilitation therapy improved symptom severity, lethargy, and stereotypy more than umbilical cord blood cell transplant plus rehabilitation therapy or rehabilitation therapy alone.^120^

##### Strength of the Evidence

Given that combination therapies were investigated in single studies, we could not make conclusions about their effects on any outcomes (insufficient strength of evidence).

#### Studies of Nutritional Supplements and Dietary Interventions

##### Key Findings

Three RCTs comparing omega-3 fatty acid supplementation with placebo reported no significant group differences in measures of challenging behavior; these studies did not consistently assess language and adaptive behavior outcomes, and no study reported clinically significant harms. While two RCTs addressed methyl B12 supplementation, results were inconsistent, with one study reporting positive effects on symptom severity^87^ and another reporting no significant effects.^83^

Four RCTs (multiple publications) compared GFCF diets to either an unaltered diet or a diet that contained gluten and dairy and reported few differences in behavioral measures between children on restricted or unrestricted diets.^63–65, 104–107^ One RCT comparing a gluten-free diet and regular diet reported significant improvements in gastrointestinal symptoms and behavior in the gluten-free group,^62^ while another comparing a gluten and dairy-free diet to usual diet reported no significant effects.^58^ Two RCTs evaluating “challenges” of gluten- or casein-containing foods reported no significant group differences in measures of challenging behavior,^59, 60^ while a high risk of bias study evaluating antioxidant-rich camel’s milk reported no significant differences in ASD severity between children receiving boiled or raw camel’s milk or cow’s milk.^61^

Despite the number of RCTs with low or moderate risk of bias addressing other supplements or diets, data are also inadequate to determine effects on any outcome in the short- or long-term. Most studies were small and short-term (ranging from 1 week to 7 months, with 24 months of treatment in one study).

##### Strength of the Evidence

Omega-3 fatty acid supplementation and placebo did not affect challenging behaviors. Our confidence in this conclusion is low (low strength of evidence for no effect) (Table 25). We also have low confidence in the conclusion that omega-3 supplementation was associated with minimal harms (low strength of evidence).

Table 25 Strength of evidence for effects of omega-3 supplementation

Intervention/Outcome Study Design Risk of Bias and Number of Studies (N Total) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Finding Strength of Evidence Grade
Omega-3 fatty acids vs. Placebo
Challenging behaviors RCT: 1 low,^81^ 2 moderate^80, 84^ N=119 | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for no effect on challenging behavior No significant differences between groups in three small, short-term RCTs
Harms RCT: 1 low,^81^ 2 moderate^80, 84^ N=119 | Medium | Consistent | Direct | Imprecise | Undetected | Low SOE for minimal harms associated with supplementation No clinically significant harms reported in any study

N = number; RCT = randomized controlled trial; SOE = strength of evidence

Data in two small studies of methyl-B12 were inadequate to draw conclusions (insufficient strength of evidence). Despite the number of RCTs with low or moderate risk of bias addressing other agents, evidence was inadequate to make conclusions about all clinical efficacy and harms outcomes because few, small, underpowered studies addressed each diet or supplement (insufficient strength of evidence).

While seven studies addressed variations of the GFCF diet, studies addressed different outcomes and different approaches to restricted and control diets; thus, data were inadequate to make conclusions about the body of evidence (insufficient strength of evidence). Data were inadequate to allow conclusions about the relative effectiveness of other dietary interventions (e.g., camels’ milk, gluten-containing challenge foods) compared with placebo (insufficient strength of evidence).

#### Studies of Risperidone Adjuncts

##### Key Findings

Despite the number of RCTs with low or moderate risk of bias, studies present little evidence to inform treatment decisions and can be considered primarily as pilot efficacy trials. All studies were short-term and lacked followup past the end of treatment. Studies included few participants (median 40 total/study) and few examined the same adjunct agent or outcomes besides the ABC Irritability subscale. Only two studies^90, 93^ addressed the same outcomes with different doses of the same agent (N-acetylcysteine). All studies except one of Gingko biloba added to risperidone reported significant improvements on the ABC-Irritability subscale in the adjunct groups compared with placebo or placebo plus risperidone; one study reporting only total ABC scores reported significant improvements in the adjunct group compared with placebo.^124^

##### Strength of the Evidence

Data were inadequate to assess effects of risperidone plus adjunctive agents including amantadine, buspirone, celecoxib, memantine, riluzole, Gingko biloba, pioglitazone, or topiramate on any outcome assessed as no study addressed the same adjunctive agent (insufficient strength of evidence). Studies were also small (<50 children in any study) and short-term (8–10 weeks of treatment). While two RCTs addressing risperidone plus N-acetylcysteine reported improvements in irritability with the combination vs. risperidone plus placebo, evidence is inadequate to comment on effects given the small number of participants (n=71 total), high attrition (15% to 30% across groups) and short-term nature (10 weeks each) of the studies (insufficient strength of evidence).

#### Studies of Hyperbaric Oxygen Therapy

##### Key Findings

Three RCTs of hyperbaric oxygen used different doses and reported inconsistent results (favorable effects associated with treatment in only one^114^ and no significant effects in two^66, 67^).

##### Strength of the Evidence

Data were inadequate to assess effects on outcomes given inconsistencies in outcome reporting (insufficient strength of evidence).

#### Studies of N-acetylcysteine

##### Key Findings

One RCT assessing N-acetylcysteine reported significant improvements in irritability (ABC-I) in treated children vs. those receiving placebo and no statistically significant effects on other measures of social skills or challenging behaviors.^78^ Another RCT reported no significant treatment effects on any outcomes (symptom severity, social skills, repetitive behaviors).^79^ Harms were not statistically significantly different between treatment and placebo groups.

##### Strength of the Evidence

N-acetylcysteine had no effect on social skills outcomes in two small RCTs; harms of this agent were not clinically significant. Our confidence in these conclusions is low (low strength of evidence) (Table 26). Data were inadequate to assess effects on other outcomes including symptom severity given inconsistent findings in these two studies (insufficient strength of evidence).

Table 26 Strength of evidence for effects of N-acetylcysteine

Intervention/Outcome Study Design Risk of Bias and Number of Studies (N Total) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Finding Strength of Evidence Grade
N-acetylcysteine vs. Placebo
Social skills RCT: 1 low,^78^ 1 moderate^79^ (N=127) | High | Consistent | Direct | Imprecise | Undetected | Low SOE for lack of effect on social skills No significant effects in either small, short-term RCT
Harms RCT: 1 low,^78^ 1 moderate^79^ (N=127) | High | Consistent | Direct | Imprecise | Undetected | Low SOE for minimal harms No study reported harms considered clinically important

N = number; RCT = randomized controlled trial; SOE = strength of evidence

#### Studies of Tetrahydrobiopterin

##### Key Findings

Outcomes were not consistent in two small RCTs of tetrahydrobiopterin.^53, 103^ Changes in symptom severity were not significantly different between treatment and placebo groups; scores on other measures of challenging and adaptive behavior improved significantly in one study.^53^ Investigators did not consider harms to be clinically significant.

##### Strength of the Evidence

Tetrahydrobiopterin had no effect on symptom severity and was not associated with significant harms. Our confidence in these conclusions is low (low strength of evidence). Data were inadequate to assess effects on other outcomes including adaptive and challenging behavior (insufficient strength of evidence). Table 27 outlines findings.

Table 27 Strength of evidence for tetrahydrobiopterin

Intervention/Outcome Study Design Risk of Bias and Number of Studies (N Total) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Finding Strength of Evidence Grade
Tetrahydrobiopterin vs. Placebo
Symptom severity RCT: 1 low^53^, 1 moderate^103^ (N=54) | High | Consistent | Direct | Imprecise | Undetected | Low SOE for lack of effect No significant effects in either small, short-term RCT
Harms RCT: 1 low^53^, 1 moderate^103^ (N=54) | High | Consistent | Direct | Imprecise | Undetected | Low SOE for minimal harms No study reported harms considered clinically important

N = number; RCT = randomized controlled trial; SOE = strength of evidence

#### Other Medical Interventions

##### Key Findings

Donepezil. Two RCTs of donepezil assessed differing outcomes and reported no effects on executive function and treatment-associated improvements in language.^11, 77^

Agents Addressed in Single Studies. Studies of citalopram,^22, 23^ and divalproex^74^ reported positive effects on measures of challenging behavior associated with treatment compared with placebo. Measures of language or symptom severity improved more in treatment arms versus control arms in studies of prednisolone,^123^ and transcranial stimulation,^69, 70^ One study of amantadine reported significant improvements in hyperactivity relative to placebo.^115^ One RCT reported improvements in time to fall asleep and sleep time with melatonin versus placebo,^68^ and one of bumetanide compared with placebo reported positive effects of bumetanide on symptom severity.^72^ Single studies of oxytocin^71^ and mecamylamine^73^ reported no significant treatment effects.

Harms reported in studies comparing these interventions were diverse, and their clinical significance is difficult to determine given the short-term nature of the studies and the typically low numbers of participants.

##### Strength of the Evidence

Data were inadequate to make conclusions about the effects amantadine, bumetanide, divalproex, oxytocin, mecamylamine, prednisolone, citalopram, melatonin, and neurostimulation vs. placebo as no studies addressed the same agents (insufficient strength of evidence).

### KQ2 Modifiers of Treatment Outcomes

Few studies reported modifying characteristics, and no characteristics were consistent modifiers.

### KQ3 Time to Effect of Interventions

Few studies reported data to assess time to effect of interventions, and the lack of data precludes conclusions.

### KQ4 Evidence That Effects Measured at the End of Treatment Predict Long-Term Functional Outcomes

Few studies had longer-term followup and those few with 6 months or more of treatment or followup typically did not report functional outcomes.

### KQ5 Effectiveness Across Environments or Contexts

Five studies reported teacher ratings of outcome measures that provide some information to address this KQ, but the limited results preclude conclusions.

### KQ6 Drivers of Treatment Outcomes

We did not identify studies that provided data to address this KQ.

## Findings in Relation to What Is Already Known

We identified 16 recent (2010–present) systematic reviews or meta-analyses addressing medical interventions for children with ASD. Three reviews evaluated the antipsychotics aripiprazole and risperidone; six evaluated multiple agents including antipsychotics; and seven evaluated agents including SSRIs, atomoxetine, gluten-free casein-free diets, omega-3 fatty acids, melatonin, and hyperbaric oxygen.

Overall, findings in these reviews generally aligned with the findings presented here, with high strength of evidence for short-term effectiveness of aripiprazole and risperidone to ameliorate challenging behaviors and high strength of evidence for adverse effects of each agent. Several reviews commented on atomoxetine as a promising agent, and one commented on melatonin to improve sleep problems. Reviews noted little evidence for gluten-free casein-free (GFCF) diets, omega-3 fatty acids, hyperbaric oxygen, antiepileptic medications, selective serotonin reuptake inhibitors (SSRIs), and chelating agents.

Reviews generally considered studies of antipsychotics to have high quality and the quality of studies addressing stimulants and atomoxetine as moderate to high. Reviews generally considered studies addressing nutritional supplements, diets and hyperbaric oxygen as moderate to low quality. Reviews consistently commented on a lack of long term data and typically small sample sizes as limitations of the strength of the evidence.

### Antipsychotics

One Cochrane review of aripiprazole included two RCTs and reported significant short-term treatment-related improvements on irritability, hyperactivity, and repetitive movement with weight gain, sedation, drooling, and neurological side effects.^133^ Another review including children with ASD (n=637), developmental disorders (n=68), or intellectual disability (n=50) noted that all of the 20 included randomized and observational studies reported significant treatment-related improvements in problem behaviors measured on the Clinical Global Impression (CGI) scale or ABC.^134^ Most studies reported adverse effects including weight gain, sedation, and tremor. Both reviews noted a need for longer term studies to address durability of effects. One meta-analysis of risperidone (n=608 children) reported a mean effect size for risperidone of 1.09 across studies (1.14 for open label studies and 1.12 for placebo-controlled) using global outcome measures such as the Childhood Autism Rating Scale (CARS) and CGI.^135^ The effect size for outcomes related to maladaptive behaviors such as irritability and aggression was 1.20.

### Reviews of Multiple Agents

Agents To Treat Irritability and Problem Behaviors. One review and meta-analysis addressed treatment of severe irritability and problem behaviors and included 11 RCTs that used the ABC-Irritability subscale in quantitative analyses. The review reported significant treatment effects for aripiprazole (effect size=0.9), risperidone (effect size=0.8), and N-acetylcysteine (effect size=0.7) compared with placebo.^136^ Harms occurring with risperidone and aripiprazole included somnolence or sedation, and extrapyramidal symptoms occurred with aripiprazole and haloperidol. Aripiprazole, risperidone, and valproate caused greater weight gain compared with placebo (effect sizes of 3.1, 0.8, and 0.3, respectively). Investigators also noted smaller effects for clonidine, methylphenidate, tianeptine, venlafaxine, and naltrexone in studies that did not specifically target irritability and that atomoxetine and dextromethorphan were associated with improvements in hyperactivity and impulsivity on the ABC-Hyperactivity subscale.

Psychotropic Medications. One review of 17 different medications reported addressed in 33 RCTS reported little established evidence to support any medication.^137^ Investigators considered aripiprazole, risperidone, haloperidol to be have established evidence for treating irritability and hyperactivity (risperidone); irritability, hyperactivity, and stereotypy (aripiprazole); and unspecified behavioral symptoms (haloperidol). The review noted promising evidence for methylphenidate’s effects on hyperactivity. Investigators considered evidence preliminary for the effects of risperidone on repetitive behavior and stereotypy, for the effects of atomoxetine and naltrexone on hyperactivity, and for pentoxifylline on irritability and social withdrawal. Investigators reported evidence as insufficient for all other agents (clonidine, guanfacine, olanzapine, divalproex, lamotrigine, levetiracetam, citalopram, fluoxetine, clomipramine, amantadine, naltrexone) on outcomes including social behavior, hyperactivity, and repetitive behavior.

Agents To Treat ADHD Symptoms. One review identified seven placebo-controlled trials of medications targeting ADHD symptoms in children with Pervasive Development Disorders (n=225 children) and reported that methylphenidate was significantly more effective than placebo in treating ADHD symptoms (effect size 0.67) and hyperactivity specifically (effect size=0.66).^138^ Appetite decrease, insomnia, depressive symptoms, irritability, and social withdrawal occurred significantly more frequently in the treatment group versus placebo. The review reported no significant effects for clonidine versus placebo and significant improvements in ADHD symptoms and hyperactivity in children taking atomoxetine compared with placebo. Harms included nausea, decreased appetite, and sleep changes.

Antiepileptic Medications. One meta-analysis evaluated valproate, lamotrigine, levetiracetam, and topiramate in children with ASD.^139^ In meta-analyses, single agents studied were not significantly different between treatment and placebo arms. One study of topiramate combined with risperidone reported improvements in irritability in the combination group compared with risperidone plus placebo. Two studies of valproate and one of levetiracetam reported no response to treatment as defined by CGI ratings. Discontinuation due to adverse effects did not differ between groups nor did the rate of total adverse events.

Alzheimer’s Medications. One review addressed use of these medications for children and adults with ASD and included case reports and other observational studies and controlled trials.^140^ Drugs assessed in children included donepezil, galantamine, rivastigmine, and memantine. Four uncontrolled and one controlled studies of donepezil reported treatment-associated improvements in ASD symptoms. All three studies of galantamine (2 RCTs and 1 case series) reported positive effects on core and associated ASD symptoms. One small case series addressing rivastigmine reported improvements in expressive language and ASD symptoms, and three studies (1 RCT, 2 case series) of memantine use in children also reported positive effects on irritability and associated symptoms with side effects including gastrointestinal symptoms, worsening behavior, and sedation. The review concluded that evidence is inconsistent and inconclusive but further study of some agents such as rivastigmine may be warranted.

Predictors of Placebo Response. One meta-analysis included data from 25 RCTs measuring outcomes with either the ABC, CGI, VABS, CARS, or Children’s Yale-Brown Obsessive Compulsive Scale (CYBOCS) and reported a moderate but significant placebo response across studies (effect size=0.45, 95% CI: 0.34 to 0.56, p<0.001).^141^ Investigators identified clinician-completed outcome measures, level of response to active intervention, a pharmacologic active intervention (vs. diet, etc.), use of adjunctive treatment, and geographical location of the trial (greater response in Iran vs. United States) as significant moderators of the placebo response, with each factor associated with an increased response.

### Reviews of Other Agents

Atomoxetine. One review of atomoxetine included six studies (1 RCT) evaluating the agent for treatment of hyperactivity in children with ADHD (n=90).^142^ All studies except one (which included children with “severe autistic disorder”) reported significant improvements in behavior in parent, teacher, and clinician ratings with treatment. Harms reported included gastrointestinal symptoms, somnolence, irritability, and weight loss; the review concluded that evidence suggests potential efficacy but small sample sizes and short-term studies limit conclusions.

Hyperbaric Oxygen Therapy. One review including eight studies (2 RCTs) reported little evidence for effects of hyperbaric oxygen in controlled trials, and some promising evidence in small case series.^143^ Few studies reported any adverse effects at the pressure levels studied.

SSRIs. One Cochrane review included nine RCTs (5 including only children) evaluating (n=239 children) evaluating the SSRIs fluoxetine, fluvoxamine, fenfluramine, and citalopram.^144^ The review reported no evidence for the effectiveness of SSRIs and potential evidence for harms.

Omega-3 Fatty Acids. One Cochrane review included two RCTs (n=37 children, predominately male with moderate to severe ASD symptoms) evaluating omega-3 fatty acids and reported no evidence for effects on social interaction, communication, hyperactivity, or stereotypy.^145^

GFCF Diets. One review included 32 studies, typically with high risk of bias, and noted scarce evidence for GFCF diets, with positive effects reported only in lower quality studies.^146^ The review concluded that evidence for the effectiveness or harms of GFCF diets is limited and weak.

Melatonin. One review included 18 studies addressing melatonin for the treatment of sleep problems in ASD.^147^ Thirteen observational studies reported improvements in sleep duration, night awakenings, or sleep onset latency, as did five RCTs. Investigators meta-analyzed RCT data and reported significant improvements on these measures with melatonin versus placebo. Harms associated with melatonin included drowsiness, gastrointestinal symptoms, and worsening behavior. No study reported serious adverse events.

Chelation. Though we did not identify studies addressing chelation agents in the current review, one Cochrane review addressed chelation therapy and included one RCT (n=49 children).^148^ Investigators considered the study to have high risk of bias and noted that no evidence suggests efficacy for ASD symptoms.

## Applicability

By definition, ASD is heterogeneous. Characterizing a “typical” child with an ASD is not possible, although certain symptoms are central to the range of children within the autism spectrum. Individual therapies are developed and tested to ameliorate specific symptoms or groups of symptoms, often in a fairly circumscribed subset of children. We provide details on the population, intervention, comparator, outcomes, and setting (PICOS) for each intervention addressed in more than one study in Appendix E to support translation of our findings and assessment of the applicability of each for differing circumstances and children.

Overall, study participants were generally recruited from specialty clinical service programs and represent nonprimary care populations. As such, families of these children may be seeking a higher level of care than those of the broader population of children with ASD based upon more severe or acute symptoms, including aggression or other challenging behaviors. Most studies of medical interventions targeted elementary school aged and older children with autism, with little data on the treatment of younger children. Most studies included majority male populations (consistent with the male prevalence of ASD).

Studies also included children with highly variable severity of challenging behaviors, ASD symptom severity, and cognitive impairment. Studies of pharmacological agents often sampled children with high levels of specific symptom patterns (e.g., children with severe challenging behavior at baseline where parents may be willing to pursue pharmacologic intervention and trial participation) who may not reflect the wider population of children with ASD in whom these challenges may not be present. Most of the studies reported including children with at least moderate level of severity of ASD. Studies of stimulants included children with cognitive impairment and with comorbidities including attention deficit hyperactivity disorder, oppositional defiant disorder, and obsessive compulsive disorder. Studies of other approaches had similarly heterogeneous populations. Dietary and nutritional studies included some younger children, with severity of autism not well described or the degree of intellectual functioning not well characterized in most studies. This heterogeneity in population characteristics may limit the generalizability of findings to children with differing levels of symptom expression or comorbidities but likely reflects the heterogeneity of the broader population of children with ASD

Studies addressed a variety of agents and typically reported use of concurrent medications or other therapies. Most agents studied are accessible in the United States, albeit with few receiving FDA approval for use. Comparators among non-placebo controlled studies varied, and few studies assessed the effect of concomitant behavioral or other therapies, though many children with ASD receive multiple interventions. The treatments studied may not adequately reflect the broad range of treatment combinations used in the general population of children with ASD.

As noted, few studies evaluated longer term treatment (>6 months); short treatment and followup periods limit our ability to understand potential longer term outcomes such as academic achievement or longer term harms. Overall, the heterogeneity of these studies parallels the heterogeneity of children with ASD, and some findings may be more applicable to children with specific levels of baseline severity or comorbidities. These limitations to generalizability likely reflect both the significant heterogeneity of ASD itself as well as its associated features, such as irritability. Thus, while there is a growing evidence base for treating certain symptoms in certain populations, these findings underscore the continued need for individualized treatment approaches that are informed by the emerging evidence base for benefits as well as harms of medical intervention, with careful consideration of symptom presentation and functioning level relative to study populations and applicability of the known literature.

## Implications for Clinical and Policy Decisionmaking

This review provides some evidence for decisionmaking about medical interventions for children with ASD. The clearest evidence favors the use of the antipsychotics risperidone and aripiprazole to address challenging behaviors in the short-term (<6 months); however, clinicians and caregivers must balance the significant harms of these agents. The significant side effect profiles make it clear that although these drugs are efficacious, caution is warranted regarding their use in patients without severe impairments or risk of injury. Few studies addressed longer term effects of these agents; thus, our confidence in longer term (>6 months) effectiveness is low. Studies of adjuncts to risperidone typically reported positive effects on challenging behaviors, but few studies addressed the same agents, precluding our ability to draw conclusions about their effectiveness.

Some evidence supports the use of methylphenidate and atomoxetine for hyperactivity, but few comparative studies addressed each agent, so our confidence in effects is limited. Given that many children with ASD are currently treated with medical interventions, strikingly little evidence exists to support clear benefit for most medical interventions, especially in the realm of interventions such as restrictive diets and supplements. Studies of nutritional supplements or specialized diets were typically underpowered and provided little evidence of effects of these approaches. Several agents were addressed in single studies, which limits conclusions about their effects.

Decisional dilemmas remain regarding characteristics of the child, family, or intervention that may modify effectiveness or predict which children may be most likely to benefit from a given approach. Similarly, the literature base is currently insufficient to inform our understanding of the time to effect of interventions, longer term effectiveness of interventions, generalizability of effects outside the treatment context, effectiveness and applicability to broader ASD populations, and components that may drive effectiveness.

## Limitations of the Comparative Effectiveness Review Process

We included studies published in English only and did not include unpublished data. We scanned a random sample of 150 non-English abstracts retrieved by our MEDLINE search. Most studies appeared to be case series, narrative reviews, basic science studies, or studies assessing etiology. Only two studies appeared to meet inclusion criteria; thus, given the high percentage of ineligible items in this scan (99%), we concluded that excluding non-English studies would not introduce significant bias into the review. We recognize that this preliminary scan did not address the entire corpus of ASD literature in other languages.

We also included only comparative studies of medical interventions with at least 10 children with ASD. To ensure comprehensive coverage of the literature, we included comparative studies with smaller sample size that would have been excluded in our 2011 review (which required a sample size of 30) in the present report. We did not conduct a de novo search for such studies but re-examined the excluded studies from the prior review. This approach may have overlooked relevant studies.

Given heterogeneity in treatment regimens, outcomes addressed in each study, and patient populations, we were limited in our ability to meta-analyze findings or identify potential subgroups that may respond more favorably to specific treatments. Finally, we used a nonvalidated tool to assess risk of bias, though we note that the tool evaluates similar constructs to those assessed in tools such as that used by the Cochrane Collaboration, with the addition of ASD-specific domains.

## Limitations of the Evidence Base

As noted, studies in the review had small sample sizes and typically limited duration of intervention and followup after intervention, despite significant improvements in study design and execution over time. Populations across studies were heterogeneous in terms of challenging behaviors, ASD symptom severity, age, and comorbidities. Few studies addressed the same agent and outcomes, and few assessed potential factors that may modify effectiveness or drive effects of interventions. Many (n=63) studies also explicitly noted that concomitant interventions were held steady during the study treatment period; however, few studies reported specific analyses to control for or assess the effects of additional treatments.

Despite these limitations, investigators have made significant improvements in incorporating commonly used measures of symptom severity and behavior to facilitate comparisons across studies. Studies also typically described interventions fully, used standardized diagnostic processes and blinded assessors, and reported on the use or restriction of concomitant interventions.

## Research Gaps and Areas for Future Research

Improving research in this area should include methodologic considerations of power and sample size and durability of effects. Sample size and participant followup were frequently insufficient to allow firm conclusions. Duration of treatment and followup were generally short (<6 months); those studies with longer duration of treatment were typically open label extensions of RCTs and lacked control arms. While duration was typically short, retaining participants in studies, especially in placebo arms, is difficult when parents or children perceive little improvement in symptoms. Longer duration of treatment, however, is also important to rule out meaningful improvements in placebo groups and help inform our understanding of the placebo effect.

Few studies provided data on long-term outcomes after cessation of treatment. Future studies should extend the followup period and assess the degree to which outcomes are durable in “real world” situations. The literature includes many single studies of various agents. Studies of adjuncts to risperidone, for example, examined different adjunct agents, with some positive effects on challenging behaviors reported with most. Understanding which agents should be examined further is lacking. Another critical area for further research is identifying which children are likely to benefit from particular interventions. To date, studies have provided limited characterization of the subpopulation of children who experience positive response to medical interventions and limited characterization of the extent or type of behavioral challenges children experience at baseline.

Children with ASD also typically receive multiple types of therapies, but few studies addressed combinations of medical and behavioral or other categories of interventions or a medical treatment compared with a nonmedical treatment. Few attempted to account for potential effects on ongoing interventions. This not only limited our ability to interpret the effects of medical treatments in isolation but represents a significant gap for families and providers in choosing additional treatments that may bolster (or impair) the effects of behavioral, medication, or other therapies. Few studies (n=10) compared active treatments, and future research to assess the comparative effectiveness of antipsychotics, ADHD medications, and other medications is necessary.

In addition, much of the medical intervention literature relies on baseline and outcome measures that have specific limits in understanding individualized response. Future research attempting to elucidate potential biobehavioral markers of response may prove useful. Research in understanding outcomes of importance to patients and caregivers, such as quality of life, is also lacking.

Harms reporting varied across studies; some studies amply described how harms were tracked, while others listed harms with no indication of how they were assessed (e.g., parent recall, checklist, clinician assessment during followup). This lack of reporting makes comparing harms across studies difficult. For instance, while studies of atomoxetine generally reported fewer harms than did studies of methylphenidate in children with ADHD symptoms, exploring differences in safety profiles is an important area for additional research.

## Conclusions

Risperidone and aripiprazole ameliorated challenging behaviors in the short term (<6 months), but had significant side effects. Methylphenidate and atomoxetine were also associated with improvements in hyperactivity in small, short-term RCTs (with uncontrolled open label extensions). Atomoxetine plus parent training was not more effective for hyperactivity than atomoxetine alone. Omega-3 fatty acid supplementation was not associated with improvements in challenging behaviors, and N-acetylcysteine and tetrahydrobiopterin were not associated with improvements in social skills and symptom severity, respectively. Some positive effects were reported with other agents studied (risperidone adjuncts, melatonin), but few studies addressed the same agent or outcomes. Data on longer term (>6 months) results and harms of interventions are lacking. Similarly, more research is needed to understand characteristics of the child or treatment that modify outcomes and whether effectiveness of interventions generalizes across different settings such as the home or school. Current evidence also does not inform our understanding of components of interventions that may drive effects. Some therapies hold promise and warrant further study, and the conduct of studies has improved considerably over time (i.e., growing number of randomized controlled trials and use of standardized measures). However, additional studies with larger, well-characterized populations over longer time frames, and that utilize transparent and rigorous methods that permit comparison across studies, would further inform decisionmaking.