# Appendix E Applicability Summary Tables

Table E-1 Antipsychotics

Domain | Description of applicability of evidence compared to question
Population | Studies typically included participants recruited from non-primary care populations (university/academic-affiliated clinics, research centers), which may limit applicability to the wider population; participants in RCTs had an average age of roughly 9 years in the treatment and comparison groups and included a mojority male subjects. In studies providing IQ data, the majority of subjects had IQs in the intellectual disability range. Studies reported use of concurrent medications but typically did not report on co-morbid conditions. Most of the studies report including children with at least moderate level of severity of ASD.
Intervention | Antipsychotics evaluated included risperidone and aripiprazole in dose ranges used in some children with ASD.
Comparators | RCTs compared treatment to placebo or to another medication (e.g., haloperidol, aripiprazole, memantine).
Outcomes | Studies primarily targeted outcomes related to problem behavior (irritability, hyperactivity) and repetitive behavior, which are significant concerns in the ASD population. Outcome measures used to assess change were appropriate; although the duration of studies was typically less than 6 months, and evaluation was typically immediately post-treatment. Some studies included open label, uncontrolled extensions. Studies reported adverse effects including sedation, weight gain, and extrapyramidal symptoms. Short-term harms and outcomes generally reflect longer-term outcomes measured over roughly 24 months.
Setting | Studies were conducted in the US, Canada, Iran, Italy, the Netherlands, Turkey, and India, primarily in academic clinics or research centers which may have yielded more selected populations.

ASD–Autism Spectrum Disorder; IQ–Intelligence Quotient; RCT–Randomized, Controlled Trial

Table E-2 Medications to treat ADHD

Domain | Description of applicability of evidence
Population | Studies included children 5 to 17 years old with autistic disorder; majority male. Studies typically included children with cognitive impairment (IQ or DQ ≤ 70) and comorbidities including ADHD, ODD, OCD, typically moderate to severe. Use of concomitant medications ranged from none to roughly a third of children in studies.
Intervention | Stimulants evaluated include different doses of methylphenidate, atomoxetine, and guanfacine.
Comparators | Placebo
Outcomes | Studies typically assessed outcomes in the short-term including hyperactivity/inattention, oppositional behavior, and social behaviors. The dose and type of medication were similar to reports in the literature; the duration of treatment across studies was 4 to 28 weeks with evaluation conducted immediately after treatment.
Setting | Studies were conducted in the US, The MPH trial included drug-free children in 5 academic outpatient clinics in the US and Netherlands, with clinic-based populations, likely representing a highly selected population.

ADHD-Attention Deficit/Hyperactivity Disorder; DQ-Developmental Quotient; MPH-methylphenidate; ODD-Oppositional Defiant Disorder; OCD-Obsessive Compulsive Disorder

Table E-3 Nutritional supplements

Domain | Description of applicability of evidence
Population | Studies included children ages 2–11 years with differing requirements for inclusion. Two omega-3 fatty acid studies targeted younger children (ages 3–8) with hyperactive behavior. The degree of intellectual disability was not well described in the studies.
Intervention | Nutritional supplements including omega-3 fatty acids, methyl B-12, peptizyde, N, N-dimethylglycine, digestive enzymes, docosahex-aenoic acid and levocarnitine.
Comparators | Comparator for all studies in this group was placebo.
Outcomes | Study outcomes included behavior, autism severity, communication, cognitive, and gastrointestinal symptoms and sleep disturbances. Data were collected using a wide range of assessment tools including CGI, ABC, CARS, SRS, BASC, GBRS, PDDBI, MCDI, PPVT, Stanford-Binet, hand muscle testing, ATEC, PIA-CV, Expressive Vocabulary test, Rescorla Language Development Survey, CBCL, and Childhood Psychiatric Rating Scale. Most studies were of 3 months duration (range 1 to 6 months). Outcomes were collected at end of treatment with no long term follow-up.
Setting | Five studies were conducted in the United States, two in Egypt and one each in the Netherlands and Australia

CGI-Clinical Global Impression; ABC-Aberrant Behavior Checklist; CARS-Childhood Autism Rating Scale; SRS-Social Responsiveness Scale; BASC-Behavioral Assessment System for Children; GBRS; Global Rating Scale; PDDBI-Pervasive Developmental Disorders Behavior Inventory; MCDI-MacArthur Communicative Development Inventory; PPVT-Peabody Picture Vocabulary Test; ATEC-Autism Treatment Evaluation Checklist; PIA-CV-Parent Interview for Autism-Clinical Version; CBCL-Child Behavior Checklist

Table E-4 Dietary interventions

Domain | Description of applicability of evidence
Population | Study participants ranged in age from 2 to 12 years, with no information available about co-morbidities, except one study that included children with severe maladaptive behavior. Severity of autism was not well described and the degree of intellectual disability was not well characterized in most studies. One GFCF study required participants to be concurrently enrolled in a comprehensive ABA program. Use of concomitant medications was not noted in most studies. One study recruited children with known allergies or food intolerances.
Intervention | Gluten-free casein-free diet, gluten-free diet, gluten dairy-free diet, raw and boiled camel milk.
Comparators | Comparators included gluten and dairy diet, gluten-containig challenge foods, usual diet, placebo and cow milk.
Outcomes | Outcomes included autism severity scores, problem behaviors including maladaptive behavior, sleep, and gastrointestinal symptoms. Assessments used in the studies included ADOS, CARS, Gilliam Autism Rating Scale (GARS), Ritvo-Freeman Real Life rating scales, ADHD-IV scale, Conner’s Behavior Rating scale, VABS, Pervasive Developmental Disorder Behavior Inventory, sleep diaries, and Gastrointestinal symptom severity index.
Setting | Studies were conducted in academic medical centers located in the United States, Belgium, Denmark, Iran, Norway, and Saudi Arabia.

CARS-Childhood Autism Rating Scale; ADOS-Autism Diagnostic Observation Schedule; ADHD-IV-Attention Deficit/Hyperactivity Disorder-IV scale; VABS-Vineland Adaptive Behavior Scales; GFCF-Gluten-free, casein-free; ABA-Applied Behavioral Analysis

Table E-5 Risperidone adjuncts

Domain | Description of applicability of evidence compared to question
Population | Studies typically included participants with autism spectrum disorder (ASD) recruited from non-primary care populations (university/academic-affiliated clinics, research centers), which may limit applicability to the wider population; participants had an average age in a range between 3–16 years and included 17–23 subjects in the treatment arm to 14–24 in the placebo arm with more male subjects (73% in treatment groups and 75% in control). Three studies reported including subjects with cognitive impairment while majority did not mention the intellectual disability status. Most of the studies included subjects with severe disruptive symptoms and typically did not report comorbidity status or use of concomitant medications or therapies.
Intervention | Risperidone adjuncts evaluated included celecoxib, Ginkgo biloba, memantine, topiramate, riluzole, buspirone, N-acetyl cysteine, amantadine, pioglitazone, galantamine, pentoxifylline, and piracetam in children with ASD.
Comparators | Studies compared adjuncts to risperidone therapy to placebo added to risperidone.
Outcomes | Studies primarily targeted outcomes related to core and associated behavior symptoms (irritability, hyperactivity, lethargy/withdrawal, stereotypy and inappropriate speech) which are significant concerns in the ASD population along with global clinical improvement. Outcome measures used to assess change were appropriate; although the duration of studies was typically ≤ 10 weeks and evaluation was typically immediately post-treatment.
Setting | All the studies were conducted in Iran and primarily in academic clinics or research centers which may have yielded more selected populations.

ASD-autsim spectrum disorder

Table E-6 Combination medical and behavioral treatments

Domain | Description of applicability of evidence
Population | Studies included children between 3 and 14 years old. Across studies ASD symptoms were generally considered mild to moderate. In one study of atomoxetine plus parent training, children had concomitant ADHD symptoms.
Intervention | Atomoxetine plus/minus parent training, bumetanide plus applied behavioral analysis; cord blood or stem cell transplantation plus rehabilitation therapy; melatonin plus/minus cognitive behavioral therapy; folic acid plus TEACCH.
Comparators | Behavioral therapy alone, placebo.
Outcomes | Most studies assessed challenging behaviors (e.g., irritability, inattention, oppositional behavior) and symptom severity; one study evaluated cognitive skills and one evaluated sleep outcomes.
Setting | Studies were conducted in China, the US, and Italy and were recruited from research centers or clinics.

ADHD-Attention Deficit/Hyperactivity Disorder; ASD-autsim spectrum disorder; TEACCH-Treatment and Education of Autistic and Communication-Related Handicapped Children

Table E-7 N-acetylcysteine

Domain | Description of applicability of evidence
Population | Studies included children between 3 and 10 years with participants recruited form the community in one study and from a clinic/hospital in another. Studies included children with and without intellectual disability. Treatment duration ranged from 12–24 weeks.
Intervention | N-acetylcysteine in doses of 500–900 milligrams.
Comparators | Placebo
Outcomes | Challenging behaviors, social and communication outcomes, adaptive behavior.
Setting | Studies were conducted in the US and Australia, with participants recruited form the community in one study and from a clinic/hospital in another.

Table E-8 Tetrahydrobiopterin

Domain | Description of applicability of evidence
Population | Studies included children between 3 and 7 years old. One study included only males. Treatment duration ranged from 16–24 weeks.
Intervention | Tetrahydrobiopterin at doses of 3 to 20 mg/kg of body weight.
Comparators | Placebo
Outcomes | The primary outcome in studies was symptom severity.
Setting | Studies were conducted in Sweden and the US with participants recruited form the community and clinic settings.

mg – milligrams; kg – kilograms

Table E-9 Other--Hyperbaric oxygen therapy

Domain | Description of applicability of evidence
Population | Studies included children ages 2–14 years with autism. The degree of disease severity was not well categorized. Participants were overwhelmingly male in the two studies that reported gender (84% and 93%) The degree of intellectual disability was not reported in any of the studies. Concomitant behavioral and medication interventions were reported in all studies.
Intervention | Hyperbaric oxygen therapy-dosages ranged from 24% to 100% oxygen.
Comparators | Comparators for these studies included treatments of room air, sham air and free air flow.
Outcomes | Study outcomes included autism severity and change in behavior. Assessment tools used in the studies included CGI (used in all three trials), ATEC, ADOS, SRS, ABC. VABS, VMI-5, BRIEF, PPVT-III, RBS and direct observation of toy play sessions. The number of treatment sessions ranged from 20 up to 80 one hour treatments occurring over a three up to 15 week period of time. Outcomes were collected at end of treatment with no long term follow-up.
Setting | Two studies were conducted in the United States and one was performed in Thailand. Participants in one study were recruited from a large community based ABA provider.

ABA – Applied Behavior Analysis; ABC – Abberant Behavior Checklist; ADOS - Autism Diagnostic Observation Schedule; ATEC – Autism Evaluation Checklist; BRIEF – Behavior Rating Inventory of Executive Function; CGI – Clinical Global Inventory; PPVT – Peabody Picture Vocabulary Test; RBS – Repetitive Behavior Scale; VABS – Vineland Adaptive Behavior Scale; VMI – Visual Motor Integration

Table E-10 Other--Bumetanide

Domain | Description of applicability of evidence
Population | Study participants ranged in age from 3 to 11 years with a wide range of disease severity among study participants. The Chinese study was restricted to younger children (2.5 to 6.5 years) who were concurrently enrolled in an ABA program. The degree of intellectual disability was not described. Concomitant medications were stopped prior to study entry in both studies. The placebo-controlled trial did allow use of melatonin.
Intervention | Bumetanide, 1 mg dose
Comparators | Placebo and no medical treatment in one study in which all participants were receiving ABA.
Outcomes | Outcomes included autism severity scores and symptoms. Assessments used in the studies included CARS, CGI, ADOS-G and ABC scales. Both studies were of 3 months duration. The placebo controlled trial also assessed subjects after a one month wash-out period post-intervention.
Setting | One placebo-controlled trial was conducted in France and the other study was done in China.

ABA-Applied Behavioral Analysis; CGI-Clinical Global Impression; CARS-Childhood Autism Rating Scale; ADOS-G-Autism Diagnostic Observation Schedule-Generic; ABC-Aberrant Behavior Checklist

Table E-11 Other--Donepezil

Domain | Description of applicability of evidence
Population | Studies included children 2 to 17 years old with autistic disorder; with majority being male children (>90%). One study reported a total ADOS score ranging from 10.2 to 11.2; with IQ ranging from 73–146 while the other did not exclude children based on intelligence or language development level. Studies allowed use of concomitant medications but did not include children with co-morbid conditions.
Intervention | The acetylcholinesterase inhibitor used was donepezil hydrochloride.
Comparators | The trial included a placebo controlled comparison group, which was an appropriate comparison group.
Outcomes | The trials ranged from 10 to 12 weeks in duration with the evaluation conducted immediately after treatment. Studies assessed outcomes in the short-term including expressive, receptive language, autistic behaviors and cognitive functioning. The dose used was similar to reports in the literature; treatment episodes were most commonly associated with mood swings, lability, diarrhea, headache and fatigue as side effects. One trial also evaluated the effect of age, IQ and autism severity on treatment response and found no significant group difference.
Setting | Both the trials were conducted in USA.

ADOS-Autism Diagnostic Observation Schedule; IQ – Intelligence Quotient