# Appendix D Risk of Bias Ratings

Table D-1 Risk of bias assessments

First Author Year | Group Design | Random Assignment | Appropriate Comparison Group | Correct Randomization | Systematic Diagnostic Approach | Clear Sample Characterization | Clear Inclusion/Exclusion Criteria | Attrition Reported | Drop out Characteristics Evaluated | Intervention Fully Described | Treatment Fidelity Monitored | Treatment Adherence Measured and Reported | Concomitant Interventions Held Steady/Reported | Outcome Measures Reliable and Valid | Primary Outcomes Specified a priori | Outcome Data Collected From Appropriate Sources | Outcomes Coded Blindly | Appropriate Statistical Analysis | Rating
Aman 2016 ^ 1 ^ | + | + | + | + | ++ | + | + | + | − | + | NA | + | + | + | + | + | + | − | Low
Aman 2015 ^2–12^ | + | + | + | + | ++ | + | + | + | + | + | + | + | + | + | + | + | + | + | Low
Amatachaya 2015 ^13, 14^ | + | + | + | + | + | − | + | − | NA | + | NA | + | + | + | + | + | + | − | Moderate
Arnold 2012 ^ 15 ^ | + | + | + | + | ++ | + | + | + | NA | + | NA | + | + | + | + | + | + | − | Low
Akhondzadeh 2010 ^ 16 ^ | + | + | + | + | − | − | + | NA | NA | + | NA | − | − | + | + | + | + | − | Moderate
Akhondzadeh 2008 ^ 17 ^ | + | + | + | + | − | − | + | + | NA | + | NA | − | + | + | + | + | + | + | Moderate
Arnold 2006 ^ 18 ^ | + | + | + | − | + | + | + | + | − | + | NA | − | + | + | + | + | + | − | moderate
Al Ayadhi 2013 ^ 19 ^ | + | + | + | − | + | − | − | + | NA | + | − | − | + | + | + | + | + | − | High
Asadabadi 2013 ^ 20 ^ | + | + | + | + | ++ | + | + | + | NA | + | NA | + | + | + | + | + | + | − | Low
Bent 2014 ^ 21 ^ | + | + | − | + | − | + | + | + | NA | + | NA | + | + | + | + | + | + | − | Moderate
Bent 2011 ^ 22 ^ | + | + | + | + | ++ | + | + | + | NA | + | NA | + | + | + | + | + | + | + | Low
Bertoglio 2010 ^ 23 ^ | + | + | + | − | ++ | + | + | + | NA | + | NA | + | + | + | + | + | + | − | Low
Chugani 2016 ^ 24 ^ | + | + | + | − | ++ | + | + | + | − | + | NA | + | + | + | + | + | + | − | Low
Cortesi 2012 ^ 25 ^ | + | + | + | + | ++ | + | + | + | + | + | NA | + | + | + | + | + | + | − | Low
Chez 2003 ^ 26 ^ | + | + | + | − | + | + | + | + | + | + | NA | − | + | + | + | + | + | − | Moderate
Dean 2016 ^ 27 ^ | + | + | + | + | + | + | + | + | − | + | NA | + | + | + | + | + | − | − | Moderate
Dadds 2014 ^ 28 ^ | + | + | + | − | + | + | + | + | − | + | NA | + | + | + | − | + | + | − | Low
Duffy 2014 ^ 29 ^ | + | − | − | NA | + | − | + | − | NA | + | NA | + | + | − | + | − | − | − | High
Findling 2014 ^ 30 ^ | + | + | + | − | ++ | + | + | + | − | + | NA | − | + | + | + | + | + | + | Low
Fahmy 2013 ^ 31 ^ | + | + | + | − | − | + | + | + | − | + | NA | − | − | + | − | + | + | − | Moderate
Ghaleiha 2016 ^ 32 ^ | + | + | + | + | ++ | + | + | + | NA | + | NA | + | + | + | + | + | + | − | Low
Ghalichi 2016 ^ 33 ^ | + | + | + | − | − | + | + | + | NA | + | NA | + | − | + | + | + | − | − | High
Ghanizadeh 2014 ^ 34 ^ | + | + | + | − | ++ | + | + | + | − | + | NA | + | + | + | + | + | + | + | Low
Geier 2011 ^ 35 ^ | + | + | + | − | − | − | − | + | − | + | NA | + | + | + | + | + | + | − | High
Granpeesheh 2010 ^ 36 ^ | + | + | + | − | ++ | − | + | + | − | + | NA | + | + | + | + | + | + | + | Low
Ghaleiha 2015 ^ 37 ^ | + | + | + | + | ++ | + | + | + | NA | + | NA | + | + | + | + | + | + | − | Low
Ghaleiha 2013 ^ 38 ^ | + | + | + | + | ++ | + | + | + | − | + | NA | + | + | + | + | + | + | + | Low
Ghaleiha 2013 ^ 39 ^ | + | + | + | + | ++ | + | + | + | NA | + | NA | + | + | + | + | + | + | − | Low
Ghaleiha 2013 ^ 40 ^ | + | + | + | + | ++ | + | + | + | − | + | NA | + | + | + | + | + | + | − | Low
Ghanizadeh 2015 ^ 41 ^ | + | + | + | + | ++ | − | + | + | − | + | NA | − | + | + | + | + | + | + | Low
Ghanizadeh 2013 ^ 42 ^ | + | + | + | + | ++ | − | + | + | − | + | NA | − | + | + | + | + | + | + | Low
Hendren 2016 ^ 43 ^ | + | + | + | + | + | + | + | + | − | + | NA | + | − | + | + | + | + | − | Moderate
Handen 2015 ^44, 45^ | + | + | + | + | ++ | + | + | + | − | + | NA | + | + | + | + | + | + | − | Low
Hyman 2015 ^ 46 ^ | + | + | + | + | ++ | + | + | + | NA | + | NA | + | + | + | + | + | + | − | Low
Handen 2011 ^ 47 ^ | + | + | + | − | ++ | + | + | + | NA | + | NA | + | + | + | + | + | + | + | Low
Hollander 2010 ^ 48 ^ | + | + | + | − | ++ | + | + | + | − | + | NA | + | + | + | + | + | + | + | Low
Hardan 2012 ^ 49 ^ | + | + | + | + | ++ | + | + | + | − | + | NA | + | + | + | + | + | + | − | Low
Hasanzadeh 2012 ^ 50 ^ | + | + | + | + | ++ | + | + | + | NA | + | NA | − | + | + | + | + | + | − | Low
Harrison 2006 ^51, 52^ | + | + | − | − | ++ | − | + | + | − | + | NA | − | − | + | + | + | + | − | Moderate
Johnson 2011 ^ 53 ^ | + | + | + | − | ++ | + | + | + | NA | + | NA | + | − | + | + | + | − | − | Moderate
King 2001 ^ 54 ^ | + | + | + | − | + | + | + | + | NA | + | NA | − | + | + | + | + | + | − | Moderate
Kent 2013 ^55, 56^ | + | + | + | + | ++ | + | + | + | − | + | NA | − | + | + | + | + | + | + | Low
King 2013 ^57, 58^ | + | + | + | + | ++ | + | + | + | + | + | NA | + | + | + | + | + | + | + | Low
Klaiman 2013 ^ 59 ^ | + | + | + | + | ++ | − | + | + | − | + | NA | + | + | + | + | + | + | − | Low
Lamberti 2016 ^ 60 ^ | + | + | + | − | ++ | + | + | + | − | + | NA | − | − | + | + | + | − | + | Low
Lv 2013 ^ 61 ^ | + | − | − | NA | ++ | − | + | + | NA | + | NA | + | + | + | + | + | − | + | High
Lemonnier 2012 ^ 62 ^ | + | + | + | − | ++ | + | + | + | NA | + | NA | − | + | + | + | + | + | − | Moderate
Mankad 2015 ^ 63 ^ | + | + | + | + | ++ | + | + | + | − | + | NA | + | + | + | + | + | + | − | Low
McCracken 2014 ^64–67^ | + | + | + | + | ++ | + | + | + | − | + | NA | − | + | + | + | + | + | + | Moderate
Mohammadi 2013 ^ 68 ^ | + | + | + | + | ++ | + | + | + | NA | + | NA | + | + | + | + | + | + | + | Low
Marcus 2011 ^69–75^ | + | + | + | + | ++ | + | + | + | − | + | NA | + | + | + | + | + | + | + | Low
Munasinghe 2010 ^ 76 ^ | + | + | + | − | − | − | + | + | − | + | NA | + | + | + | + | + | + | − | Moderate
Miral 2008 ^ 77 ^ | + | + | + | + | + | + | + | + | NA | + | NA | + | + | + | + | + | + | + | Moderate
Nikvarz 2016 ^ 78 ^ | + | + | + | + | + | − | + | + | − | + | NA | − | + | + | + | + | − | − | Moderate
Navarro 2015 ^ 79 ^ | + | + | + | + | ++ | + | + | + | NA | + | NA | + | − | + | + | + | + | − | Low
Nikoo 2014 ^ 80 ^ | + | + | + | + | + | + | + | + | − | + | NA | − | + | + | + | + | + | + | Moderate
Nagaraj 2006 ^ 81 ^ | + | + | + | + | + | + | + | + | − | + | NA | − | + | + | + | + | + | − | Moderate
Pusponegoro 2015 ^ 82 ^ | + | + | + | + | − | + | + | + | − | + | + | + | − | + | + | + | + | − | Moderate
Pearson 2013 ^ 83 ^ | + | + | + | − | ++ | + | + | + | NA | + | NA | + | + | + | + | + | + | + | Low
Rezaei 2010 ^ 84 ^ | + | + | + | + | ++ | + | + | + | NA | + | NA | + | + | + | + | + | + | + | Low
Rossignol 2009 ^ 85 ^ | + | + | + | + | ++ | + | + | + | + | + | NA | − | + | + | + | + | + | − | Low
Sun 2016 ^ 86 ^ | + | − | + | NA | + | + | + | + | − | + | NA | + | + | + | + | + | − | − | Moderate
Sampanthavivat 2012 ^ 87 ^ | + | + | + | + | + | − | + | + | NA | + | NA | + | − | + | + | + | + | − | Moderate
Shea 2004 ^88, 89^ | + | + | + | − | + | + | + | + | − | + | NA | + | + | + | + | + | + | − | Moderate
Saad 2015 ^ 90 ^ | + | + | + | + | ++ | + | − | + | NA | + | NA | − | + | + | + | + | + | − | Moderate
Scahill 2015 ^ 91 ^ | + | + | + | + | ++ | + | + | + | + | + | NA | + | + | + | + | + | + | + | Low
Shan 2015 ^ 92 ^ | + | + | + | − | − | − | + | + | − | + | NA | − | − | + | − | + | − | − | High
Troost 2005 ^ 93 ^ | + | + | + | − | ++ | + | + | + | NA | + | NA | − | + | + | + | + | + | + | Low
Voigt 2014 ^ 94 ^ | + | + | + | + | ++ | + | + | + | − | + | NA | + | + | + | + | + | + | + | Low
Van der Meer 2013 ^95–98^ | + | + | + | + | ++ | + | + | + | NA | + | NA | + | + | + | + | + | + | − | Low
Wink 2014 ^ 99 ^ | + | − | + | NA | + | + | − | − | − | + | − | + | + | + | + | − | + | + | Moderate
Wright 2011 ^ 100 ^ | + | + | + | + | ++ | + | + | + | − | + | NA | + | + | + | + | + | + | − | Low
Whiteley 2010 ^101, 102^ | + | + | + | − | ++ | + | + | + | − | + | NA | + | + | + | + | + | − | − | Moderate
Wasserman 2006 ^ 103 ^ | + | + | + | − | ++ | + | + | + | − | + | NA | − | + | + | + | + | + | − | Low
Danfors 2005 ^ 104 ^ | + | + | + | − | + | + | + | + | NA | + | NA | + | − | + | + | + | + | + | Moderate
Knivsberg 2002 ^105_4575^ | + | + | + | − | − | + | + | + | NA | − | NA | − | − | + | + | + | + | − | High

## References

1 Aman MG, Findling RL, Hardan AY, . Safety and Efficacy of Memantine in Children with Autism: Randomized, Placebo-Controlled Study and Open-Label Extension. J Child Adolesc Psychopharmacol. 2016 Mar 15PMID: 26978327.26978327
2 Aman M, Rettiganti M, Nagaraja HN, . Tolerability, Safety, and Benefits of Risperidone in Children and Adolescents with Autism: 21-Month Follow-up After 8-Week Placebo-Controlled Trial. J Child Adolesc Psychopharmacol 2015 Aug;25(6):482–93. PMID: 26262903.26262903
3 Scahill L, Sukhodolsky DG, Anderberg E, . Sensitivity of the modified Children’s Yale-Brown Obsessive Compulsive Scale to detect change: Results from two multi-site trials. Autism. 2015 Apr 16PMID: 25882391.25882391
4 Scahill L, Hallett V, Aman MG, . Brief Report: social disability in autism spectrum disorder: results from Research Units on Pediatric Psychopharmacology (RUPP) Autism Network trials. J Autism Dev Disord 2013 Mar;43(3):739–46. PMID: 23104617.23104617
5 Arnold LE, Farmer C, Kraemer HC, . Moderators, mediators, and other predictors of risperidone response in children with autistic disorder and irritability. J Child Adolesc Psychopharmacol 2010 Apr;20(2):83–93. PMID: 20415603.20415603
6 Aman MG, Hollway JA, McDougle CJ, . Cognitive effects of risperidone in children with autism and irritable behavior. J Child Adolesc Psychopharmacol 2008 Jun;18(3):227–36. PMID: 18582177.18582177
7 Aman MG, Arnold LE, McDougle CJ, . Acute and long-term safety and tolerability of risperidone in children with autism. J Child Adolesc Psychopharmacol 2005 Dec;15(6):869–84. PMID: 16379507.16379507
8 McDougle CJ, Scahill L, Aman MG, . Risperidone for the core symptom domains of autism: results from the study by the autism network of the research units on pediatric psychopharmacology. Am J Psychiatry 2005 Jun;162(6):1142–8. PMID: 15930063.15930063
9 Martin A, Scahill L, Anderson GM, . Weight and leptin changes among risperidone-treated youths with autism: 6-month prospective data. Am J Psychiatry 2004 Jun;161(6):1125–7. PMID: 15169706.15169706
10 McCracken JT, McGough J, Shah B, . Risperidone in children with autism and serious behavioral problems. N Engl J Med 2002 Aug 1;347(5):314–21. PMID: 12151468.12151468
11 Arnold LE, Vitiello B, McDougle C, . Parent-defined target symptoms respond to risperidone in RUPP autism study: customer approach to clinical trials. J Am Acad Child Adolesc Psychiatry 2003 Dec;42(12):1443–50. PMID: 14627879.14627879
12 Risperidone treatment of autistic disorder: longer-term benefits and blinded discontinuation after 6 months. Am J Psychiatry 2005 Jul;162(7):1361–9. PMID: 15994720.15994720
13 Amatachaya A, Jensen MP, Patjanasoontorn N, . The short-term effects of transcranial direct current stimulation on electroencephalography in children with autism: a randomized crossover controlled trial. Behav Neurol 2015;2015:928631. PMID: 25861158.25861158
14 Amatachaya A, Auvichayapat N, Patjanasoontorn N, . Effect of anodal transcranial direct current stimulation on autism: a randomized double-blind crossover trial. Behav Neurol 2014;2014:173073. PMID: 25530675.25530675
15 Arnold LE, Aman MG, Hollway J, . Placebo-controlled pilot trial of mecamylamine for treatment of autism spectrum disorders. J Child Adolesc Psychopharmacol 2012 Jun;22(3):198–205. PMID: 22537359.22537359
16 Akhondzadeh S, Fallah J, Mohammadi MR, . Double-blind placebo-controlled trial of pentoxifylline added to risperidone: effects on aberrant behavior in children with autism. Prog Neuropsychopharmacol Biol Psychiatry 2010 Feb 1;34(1):32–6. PMID: 19772883.19772883
17 Akhondzadeh S, Tajdar H, Mohammadi MR, . A double-blind placebo controlled trial of piracetam added to risperidone in patients with autistic disorder. Child Psychiatry Hum Dev 2008 Sep;39(3):237–45. PMID: 17929164.17929164
18 Arnold LE, Aman MG, Cook AM, . Atomoxetine for hyperactivity in autism spectrum disorders: placebo-controlled crossover pilot trial. J Am Acad Child Adolesc Psychiatry 2006 Oct;45(10):1196–205. PMID: 17003665.17003665
19 Al-Ayadhi LY, Elamin NE. Camel Milk as a Potential Therapy as an Antioxidant in Autism Spectrum Disorder (ASD). Evid Based Complement Alternat Med 2013;2013:602834. PMID: 24069051.24069051
20 Asadabadi M, Mohammadi MR, Ghanizadeh A, . Celecoxib as adjunctive treatment to risperidone in children with autistic disorder: a randomized, double-blind, placebo-controlled trial. Psychopharmacology (Berl) 2013 Jan;225(1):51–9. PMID: 22782459.22782459
21 Bent S, Hendren RL, Zandi T, . Internet-based, randomized, controlled trial of omega-3 fatty acids for hyperactivity in autism. J Am Acad Child Adolesc Psychiatry 2014 Jun;53(6):658–66. PMID: 24839884.24839884
22 Bent S, Bertoglio K, Ashwood P, . A pilot randomized controlled trial of omega-3 fatty acids for autism spectrum disorder. J Autism Dev Disord 2011 May;41(5):545–54. PMID: 20683766.20683766
23 Bertoglio K, Jill James S, Deprey L, . Pilot study of the effect of methyl B12 treatment on behavioral and biomarker measures in children with autism. J Altern Complement Med 2010 May;16(5):555–60. PMID: 20804367.20804367
24 Chugani DC, Chugani HT, Wiznitzer M, . Efficacy of Low-Dose Buspirone for Restricted and Repetitive Behavior in Young Children with Autism Spectrum Disorder: A Randomized Trial. J Pediatr 2016 Mar;170:45–53.e1–4. PMID: 26746121.26746121
25 Cortesi F, Giannotti F, Sebastiani T, . Controlled-release melatonin, singly and combined with cognitive behavioural therapy, for persistent insomnia in children with autism spectrum disorders: a randomized placebo-controlled trial. J Sleep Res 2012 Dec;21(6):700–9. PMID: 22616853.22616853
26 Chez MG, Buchanan TM, Becker M, . Donepezil hydrochloride: A double-blind study in autistic children. Journal of Pediatric Neurology 2003 Oct–Dec;1(2):83–8.
27 Dean OM, Gray KM, Villagonzalo KA, . A randomised, double blind, placebo-controlled trial of a fixed dose of N-acetyl cysteine in children with autistic disorder. Aust N Z J Psychiatry. 2016 Jun 17PMID: 27316706.27316706
28 Dadds MR, MacDonald E, Cauchi A, . Nasal oxytocin for social deficits in childhood autism: a randomized controlled trial. J Autism Dev Disord 2014 Mar;44(3):521–31. PMID: 23888359.23888359
29 Duffy FH, Shankardass A, McAnulty GB, . Corticosteroid therapy in regressive autism: a retrospective study of effects on the Frequency Modulated Auditory Evoked Response (FMAER), language, and behavior. BMC Neurol 2014;14:70. PMID: 24885033.24885033
30 Findling RL, Mankoski R, Timko K, . A randomized controlled trial investigating the safety and efficacy of aripiprazole in the long-term maintenance treatment of pediatric patients with irritability associated with autistic disorder. J Clin Psychiatry 2014 Jan;75(1):22–30. PMID: 24502859.24502859
31 Fahmy SF, El-hamamsy MH, Zaki OK, . L-Carnitine supplementation improves the behavioral symptoms in autistic children. Research in Autism Spectrum Disorders 2013;7(1):159–66. 2012-29769-018.
32 Ghaleiha A, Alikhani R, Kazemi MR, . Minocycline as Adjunctive Treatment to Risperidone in Children with Autistic Disorder: A Randomized, Double-Blind Placebo-Controlled Trial. J Child Adolesc Psychopharmacol. 2016 Apr 29PMID: 27128958.27128958
33 Ghalichi F, Ghaemmaghami J, Malek A, . Effect of gluten free diet on gastrointestinal and behavioral indices for children with autism spectrum disorders: a randomized clinical trial. World J Pediatr. 2016 Jun 10PMID: 27286693.27286693
34 Ghanizadeh A, Sahraeizadeh A, Berk M. A head-to-head comparison of aripiprazole and risperidone for safety and treating autistic disorders, a randomized double blind clinical trial. Child Psychiatry Hum Dev 2014;45(2):185–92. PMID: 23801256.23801256
35 Geier DA, Kern JK, Davis G, . A prospective double-blind, randomized clinical trial of levocarnitine to treat autism spectrum disorders. Med Sci Monit. 2011 Jun;17(6):Pi15–23. PMID: 21629200.21629200
36 Granpeesheh D, Tarbox J, Dixon DR, . Randomized trial of hyperbaric oxygen therapy for children with autism. Research in Autism Spectrum Disorders 2010 April 2010/June;4(2):268–75. .
37 Ghaleiha A, Rasa SM, Nikoo M, . A pilot double-blind placebo-controlled trial of pioglitazone as adjunctive treatment to risperidone: Effects on aberrant behavior in children with autism. Psychiatry Res 2015 Sep 30;229(1–2):181–7. PMID: 26208985.26208985
38 Ghaleiha A, Mohammadi E, Mohammadi MR, . Riluzole as an adjunctive therapy to risperidone for the treatment of irritability in children with autistic disorder: a double-blind, placebo-controlled, randomized trial. Paediatr Drugs 2013 Dec;15(6):505–14. PMID: 23821414.23821414
39 Ghaleiha A, Asadabadi M, Mohammadi MR, . Memantine as adjunctive treatment to risperidone in children with autistic disorder: a randomized, double-blind, placebo-controlled trial. Int J Neuropsychopharmacol 2013 May;16(4):783–9. PMID: 22999292.22999292
40 Ghaleiha A, Ghyasvand M, Mohammadi MR, . Galantamine efficacy and tolerability as an augmentative therapy in autistic children: A randomized, double-blind, placebo-controlled trial. J Psychopharmacol 2013 Oct 15;28(7):677–85. PMID: 24132248.24132248
41 Ghanizadeh A, Ayoobzadehshirazi A. A randomized double-blind placebo-controlled clinical trial of adjuvant buspirone for irritability in autism. Pediatr Neurol 2015 Jan;52(1):77–81. PMID: 25451017.25451017
42 Ghanizadeh A, Moghimi-Sarani E. A randomized double blind placebo controlled clinical trial of N-Acetylcysteine added to risperidone for treating autistic disorders. BMC Psychiatry 2013;13:196. PMID: 23886027.23886027
43 Hendren RL, James SJ, Widjaja F, . Randomized, Placebo-Controlled Trial of Methyl B12 for Children with Autism. J Child Adolesc Psychopharmacol. 2016 Feb 18PMID: 26889605.26889605
44 Handen BL, Aman MG, Arnold LE, . Atomoxetine, Parent Training, and Their Combination in Children With Autism Spectrum Disorder and Attention-Deficit/Hyperactivity Disorder. J Am Acad Child Adolesc Psychiatry 2015 Nov;54(11):905–15. PMID: 26506581.26506581
45 Smith T, Aman MG, Arnold LE, . Atomoxetine and Parent Training for Children With Autism and Attention-Deficit/Hyperactivity Disorder: A 24-Week Extension Study. J Am Acad Child Adolesc Psychiatry 2016 Oct;55(10):868–76.e2. PMID: 27663942.27663942
46 Hyman SL, Stewart PA, Foley J, . The Gluten-Free/Casein-Free Diet: A Double-Blind Challenge Trial in Children with Autism. J Autism Dev Disord. 2015 Sep 5PMID: 26343026.26343026
47 Handen BL, Johnson CR, McAuliffe-Bellin S, . Safety and efficacy of donepezil in children and adolescents with autism: neuropsychological measures. J Child Adolesc Psychopharmacol 2011 Feb;21(1):43–50. PMID: 21309696.21309696
48 Hollander E, Chaplin W, Soorya L, . Divalproex sodium vs placebo for the treatment of irritability in children and adolescents with autism spectrum disorders. Neuropsychopharmacology 2010 Mar;35(4):990–8. PMID: 20010551.20010551
49 Hardan AY, Fung LK, Libove RA, . A randomized controlled pilot trial of oral N-acetylcysteine in children with autism. Biol Psychiatry 2012 Jun 1;71(11):956–61. PMID: 22342106.22342106
50 Hasanzadeh E, Mohammadi MR, Ghanizadeh A, . A double-blind placebo controlled trial of Ginkgo biloba added to risperidone in patients with autistic disorders. Child Psychiatry Hum Dev 2012 Oct;43(5):674–82. PMID: 22392415.22392415
51 Harrison Elder J, Shankar M, Shuster J, . The Gluten-Free, Casein-Free Diet In Autism: Results of A Preliminary Double Blind Clinical Trial. Journal of Autism and Developmental Disorders 2006 Apr;36(3):413–20. PMID: 2006-07517-011.16555138
52 Seung H, Rogalski Y, Shankar M, . The gluten- and casein-free diet and autism: Communication outcomes from a preliminary double-blind clinical trial. Journal of Medical Speech-Language Pathology 2007 Dec;15(4):337–45.
53 Johnson CR, Handen BL, Zimmer M, . Effects of gluten free / casein free diet in young children with autism: A pilot study. Journal of Developmental and Physical Disabilities 2011 2015-12-09;23(3):213–25. 2011-08445-004.
54 King BH, Wright DM, Handen BL, . Double-blind, placebo-controlled study of amantadine hydrochloride in the treatment of children with autistic disorder. J Am Acad Child Adolesc Psychiatry 2001 Jun;40(6):658–65. PMID: 11392343.11392343
55 Kent JM, Kushner S, Ning X, . Risperidone dosing in children and adolescents with autistic disorder: a double-blind, placebo-controlled study. J Autism Dev Disord 2013 Aug;43(8):1773–83. PMID: 23212807.23212807
56 Kent JM, Hough D, Singh J, . An open-label extension study of the safety and efficacy of risperidone in children and adolescents with autistic disorder. J Child Adolesc Psychopharmacol 2013 Dec;23(10):676–86. PMID: 24350813.24350813
57 King BH, Dukes K, Donnelly CL, . Baseline factors predicting placebo response to treatment in children and adolescents with autism spectrum disorders: a multisite randomized clinical trial. JAMA Pediatr 2013 Nov;167(11):1045–52. PMID: 24061784.24061784
58 King BH, Hollander E, Sikich L, . Lack of efficacy of citalopram in children with autism spectrum disorders and high levels of repetitive behavior: citalopram ineffective in children with autism. Arch Gen Psychiatry 2009 Jun;66(6):583–90. PMID: 19487623.19487623
59 Klaiman C, Huffman L, Masaki L, . Tetrahydrobiopterin as a treatment for autism spectrum disorders: a double-blind, placebo-controlled trial. J Child Adolesc Psychopharmacol 2013 Jun;23(5):320–8. PMID: 23782126.23782126
60 Lamberti M, Siracusano R, Italiano D, . Head-to-Head Comparison of Aripiprazole and Risperidone in the Treatment of ADHD Symptoms in Children with Autistic Spectrum Disorder and ADHD: A Pilot, Open-Label, Randomized Controlled Study. Paediatr Drugs 2016 Aug;18(4):319–29. PMID: 27278054.27278054
61 Lv YT, Zhang Y, Liu M, . Transplantation of human cord blood mononuclear cells and umbilical cord-derived mesenchymal stem cells in autism. J Transl Med 2013;11:196. PMID: 23978163.23978163
62 Lemonnier E, Degrez C, Phelep M, . A randomised controlled trial of bumetanide in the treatment of autism in children. Transl Psychiatry 2012;2:e202. PMID: 23233021.23233021
63 Mankad D, Dupuis A, Smile S, . A randomized, placebo controlled trial of omega-3 fatty acids in the treatment of young children with autism. Mol Autism 2015;6:18. PMID: 25798215.25798215
64 McCracken JT, Badashova KK, Posey DJ, . Positive effects of methylphenidate on hyperactivity are moderated by monoaminergic gene variants in children with autism spectrum disorders. Pharmacogenomics J 2014 Jun;14(3):295–302. PMID: 23856854.23856854
65 Posey DJ, Aman MG, McCracken JT, . Positive effects of methylphenidate on inattention and hyperactivity in pervasive developmental disorders: an analysis of secondary measures. Biol Psychiatry 2007 Feb 15;61(4):538–44. PMID: 17276750.17276750
66 Jahromi LB, Kasari CL, McCracken JT, . Positive Effects of Methylphenidate on Social Communication and Self-Regulation in Children with Pervasive Developmental Disorders and Hyperactivity. Journal of Autism and Developmental Disorders 2009 Mar;39(3):395–404. PMID: 18752063
67 Randomized, controlled, crossover trial of methylphenidate in pervasive developmental disorders with hyperactivity. Arch Gen Psychiatry 2005 Nov;62(11):1266–74. PMID: 16275814.16275814
68 Mohammadi MR, Yadegari N, Hassanzadeh E, . Double-blind, placebo-controlled trial of risperidone plus amantadine in children with autism: a 10-week randomized study. Clin Neuropharmacol. 2013 Nov–Dec;36(6):179–84. PMID: 24201232.24201232
69 Marcus RN, Owen R, Manos G, . Aripiprazole in the treatment of irritability in pediatric patients (aged 6–17 years) with autistic disorder: results from a 52-week, open-label study. J Child Adolesc Psychopharmacol 2011 Jun;21(3):229–36. PMID: 21663425.21663425
70 Aman MG, Kasper W, Manos G, . Line-item analysis of the Aberrant Behavior Checklist: results from two studies of aripiprazole in the treatment of irritability associated with autistic disorder. J Child Adolesc Psychopharmacol 2010 Oct;20(5):415–22. PMID: 20973712.20973712
71 Varni JW, Handen BL, Corey-Lisle PK, . Effect of aripiprazole 2 to 15 mg/d on health-related quality of life in the treatment of irritability associated with autistic disorder in children: a post hoc analysis of two controlled trials. Clin Ther 2012 Apr;34(4):980–92. PMID: 22444782.22444782
72 Amoros E, Tzvetkovitch A. [Aquatic therapy for children with autism]. Soins Pediatr Pueric 2014 Jan–Feb(276):29–30. PMID: 24617090.24617090
73 Robb AS, Andersson C, Bellocchio EE, . Safety and tolerability of aripiprazole in the treatment of irritability associated with autistic disorder in pediatric subjects (6–17 years old):results from a pooled analysis of 2 studies. Prim Care Companion CNS Disord 2011;13(1)PMID: 21731831.21731831
74 Marcus RN, Owen R, Kamen L, . A placebo-controlled, fixed-dose study of aripiprazole in children and adolescents with irritability associated with autistic disorder. J Am Acad Child Adolesc Psychiatry 2009 Nov;48(11):1110–9. PMID: 19797985.19797985
75 Owen R, Sikich L, Marcus RN, . Aripiprazole in the treatment of irritability in children and adolescents with autistic disorder. Pediatrics 2009 Dec;124(6):1533–40. PMID: 19948625.19948625
76 Munasinghe SA, Oliff C, Finn J, . Digestive enzyme supplementation for autism spectrum disorders: a double-blind randomized controlled trial. J Autism Dev Disord 2010 Sep;40(9):1131–8. PMID: 20204691.20204691
77 Miral S, Gencer O, Inal-Emiroglu FN, . Risperidone versus haloperidol in children and adolescents with AD : a randomized, controlled, double-blind trial. Eur Child Adolesc Psychiatry 2008 Feb;17(1):1–8. PMID: 18080171.18080171
78 Nikvarz N, Alaghband-Rad J, Tehrani-Doost M, . Comparing Efficacy and Side Effects of Memantine vs. Risperidone in the Treatment of Autistic Disorder. Pharmacopsychiatry 2016 Jun 14PMID: 27299475.27299475
79 Navarro F, Pearson DA, Fatheree N, . Are ‘leaky gut’ and behavior associated with gluten and dairy containing diet in children with autism spectrum disorders? Nutr Neurosci 2015 May;18(4):177–85. PMID: 24564346.24564346
80 Nikoo M, Radnia H, Farokhnia M, . N-acetylcysteine as an adjunctive therapy to risperidone for treatment of irritability in autism: a randomized, double-blind, placebo-controlled clinical trial of efficacy and safety. Clin Neuropharmacol. 2015 Jan–Feb;38(1):11–7. PMID: 25580916.25580916
81 Nagaraj R, Singhi P, Malhi P. Risperidone in children with autism: randomized, placebo-controlled, double-blind study. J Child Neurol 2006 Jun;21(6):450–5. PMID: 16948927.16948927
82 Pusponegoro HD, Ismael S, Firmansyah A, . Gluten and casein supplementation does not increase symptoms in children with autism spectrum disorder. Acta Paediatr 2015 Nov;104(11):e500–e5. PMID: 26148018.26148018
83 Pearson DA, Santos CW, Aman MG, . Effects of extended release methylphenidate treatment on ratings of attention-deficit/hyperactivity disorder (ADHD) and associated behavior in children with autism spectrum disorders and ADHD symptoms. J Child Adolesc Psychopharmacol 2013 Jun;23(5):337–51. PMID: 23782128.23782128
84 Rezaei V, Mohammadi MR, Ghanizadeh A, . Double-blind, placebo-controlled trial of risperidone plus topiramate in children with autistic disorder. Prog Neuropsychopharmacol Biol Psychiatry 2010 Oct 1;34(7):1269–72. PMID: 20637249.20637249
85 Rossignol DA, Rossignol LW, Smith S, . Hyperbaric treatment for children with autism: a multicenter, randomized, double-blind, controlled trial. BMC Pediatr 2009;9:21. PMID: 19284641.19284641
86 Sun C, Zou M, Zhao D, . Efficacy of Folic Acid Supplementation in Autistic Children Participating in Structured Teaching: An Open-Label Trial. Nutrients 2016;8(6)PMID: 27338456.27338456
87 Sampanthavivat M, Singkhwa W, Chaiyakul T, . Hyperbaric oxygen in the treatment of childhood autism: a randomised controlled trial. Diving Hyperb Med 2012 Sep;42(3):128–33. PMID: 22987458.22987458
88 Shea S, Turgay A, Carroll A, . Risperidone in the treatment of disruptive behavioral symptoms in children with autistic and other pervasive developmental disorders. Pediatrics 2004 Nov;114(5):e634–41. PMID: 15492353.15492353
89 Pandina GJ, Bossie CA, Youssef E, . Risperidone improves behavioral symptoms in children with autism in a randomized, double-blind, placebo-controlled trial. J Autism Dev Disord 2007 Feb;37(2):367–73. PMID: 17019624.17019624
90 Saad K, Eltayeb AA, Mohamad IL, . A Randomized, Placebo-controlled Trial of Digestive Enzymes in Children with Autism Spectrum Disorders. Clin Psychopharmacol Neurosci 2015 Aug 31;13(2):188–93. PMID: 26243847.26243847
91 Scahill L, McCracken JT, King BH, . Extended-Release Guanfacine for Hyperactivity in Children With Autism Spectrum Disorder. Am J Psychiatry. 2015 Aug 28:appiajp201515010055. PMID: 26315981.26315981
92 Du L, Shan L, Wang B, . A Pilot Study on the Combination of Applied Behavior Analysis and Bumetanide Treatment for Children with Autism. J Child Adolesc Psychopharmacol 2015 Sep;25(7):585–8. PMID: 26258842.26258842
93 Troost PW, Lahuis BE, Steenhuis MP, . Long-term effects of risperidone in children with autism spectrum disorders: a placebo discontinuation study. J Am Acad Child Adolesc Psychiatry 2005 Nov;44(11):1137–44. PMID: 16239862.16239862
94 Voigt RG, Mellon MW, Katusic SK, . Dietary docosahexaenoic acid supplementation in children with autism. J Pediatr Gastroenterol Nutr 2014 Jun;58(6):715–22. PMID: 24345834.24345834
95 van der Meer JM, Harfterkamp M, van de Loo-Neus G, . A randomized, double-blind comparison of atomoxetine and placebo on response inhibition and interference control in children and adolescents with autism spectrum disorder and comorbid attention-deficit/hyperactivity disorder symptoms. J Clin Psychopharmacol 2013 Dec;33(6):824–7. PMID: 24018545.24018545
96 Harfterkamp M, Buitelaar JK, Minderaa RB, . Atomoxetine in autism spectrum disorder: no effects on social functioning; some beneficial effects on stereotyped behaviors, inappropriate speech, and fear of change. J Child Adolesc Psychopharmacol 2014 Nov;24(9):481–5. PMID: 25369243.25369243
97 Harfterkamp M, van de Loo-Neus G, Minderaa RB, . A randomized double-blind study of atomoxetine versus placebo for attention-deficit/hyperactivity disorder symptoms in children with autism spectrum disorder. J Am Acad Child Adolesc Psychiatry 2012 Jul;51(7):733–41. PMID: 22721596.22721596
98 Harfterkamp M, Buitelaar JK, Minderaa RB, . Long-term treatment with atomoxetine for attention-deficit/hyperactivity disorder symptoms in children and adolescents with autism spectrum disorder: an open-label extension study. J Child Adolesc Psychopharmacol 2013 Apr;23(3):194–9. PMID: 23578015.23578015
99 Wink LK, Early M, Schaefer T, . Body mass index change in autism spectrum disorders: comparison of treatment with risperidone and aripiprazole. J Child Adolesc Psychopharmacol 2014 Mar;24(2):78–82. PMID: 24564519.24564519
100 Wright B, Sims D, Smart S, . Melatonin versus placebo in children with autism spectrum conditions and severe sleep problems not amenable to behaviour management strategies: a randomised controlled crossover trial. J Autism Dev Disord 2011 Feb;41(2):175–84. PMID: 20535539.20535539
101 Whiteley P, Haracopos D, Knivsberg AM, . The ScanBrit randomised, controlled, single-blind study of a gluten- and casein-free dietary intervention for children with autism spectrum disorders. Nutr Neurosci 2010 Apr;13(2):87–100. PMID: 20406576.20406576
102 Pedersen L, Parlar S, Kvist K, . Data mining the ScanBrit study of a gluten- and casein-free dietary intervention for children with autism spectrum disorders: behavioural and psychometric measures of dietary response. Nutr Neurosci 2014 Sep;17(5):207–13. PMID: 24075141.24075141
103 Wasserman S, Iyengar R, Chaplin WF, . Levetiracetam versus placebo in childhood and adolescent autism: a double-blind placebo-controlled study. Int Clin Psychopharmacol 2006 Nov;21(6):363–7. PMID: 17012983.17012983
104 Danfors T, von Knorring AL, Hartvig P, . Tetrahydrobiopterin in the treatment of children with autistic disorder: a double-blind placebo-controlled crossover study. J Clin Psychopharmacol 2005 Oct;25(5):485–9. PMID: 16160627.16160627
105 Knivsberg AM, Reichelt KL, Hoien T, . A randomised, controlled study of dietary intervention in autistic syndromes. Nutr Neurosci 2002 Sep;5(4):251–61. PMID: 12168688.12168688