# Appendix B Screening and Risk of Bias Assessment Forms

Medical and Sensory-Related Therapies for Children with Autism Spectrum Disorder Abstract Review Form

Medical and Sensory-Related Therapies for Children with Autism Spectrum Disorder Full Text Review Form

Medical and Sensory-Related Therapies for Children with Autism Spectrum Disorder Risk of Bias Form