# Appendix A Search Strategies

Table A-1 Treatment/intervention

Interface: PubMed; Database: Medline

| Search | Records
1 | “Child Development Disorders, Pervasive”[Mesh] | 22690
2 | (autistic[tiab] OR autism[tiab] OR asperger[tiab] OR asperger’s[tiab] OR aspergers[tiab] OR pervasive development[tiab] OR pervasive developmental[tiab] OR pdd[tiab]) NOT medline[sb] | 5613
3 | #1 OR #2 | 28303
4 | therapy[sh] OR therapeutics[mh] OR psychotherapy[mh] OR treatment outcome[mh] | 7271756
5 | (treatment[tiab] OR therapy[tiab] OR intervention[tiab] OR “control group”[tiab] OR randomized[tiab] OR outcome[tiab] OR randomized[tiab] OR efficacy[tiab] OR effectiveness[tiab] OR comparison[tiab] OR compared[tiab] OR trial[tiab] OR “pilot study”[tiab] ) NOT medline[sb] | 794459
6 | #4 OR #5 | 8058741
7 | #3 AND #6 | 9859
8 | (newspaper article[pt] OR comment[pt] OR case reports[pt] OR review[pt] OR practice guideline[pt] OR news[pt] OR editorial[pt] OR historical article[pt] OR meta-analysis[pt] OR legal cases[pt] OR published erratum[pt] OR congresses[pt]) | 5128288
9 | #7 NOT #8 | 6801
10 | #9 limited to (“2010/01/01”[Date - Publication] : “3000”[Date - Publication]) | 3894

Key: [mh] Medical Subject Heading; [tiab] title/abstract word; [pt] publication type; [sh] subheading; [dp] publication date; [la] language; [pt] publication type.

Table A-2 Medication

Interface: EBSCOhost; Database: CINAHL

| Search | Records
1 | (MH “Autistic Disorder”) | 10,856
2 | (MH “Child Development Disorders”) OR (MH “Child Development Disorders, Pervasive”) | 2,067
3 | “autism” | 8,856
4 | #2 AND #3 | 511
5 | #1 OR #4 | 11,134
6 | (MH “Psychopharmacology”) OR (MH “Central Nervous System Agents+”) | 92,105
7 | (MM “Autistic Disorder/DT”) | 237
8 | #6 OR #7 | 92,210
9 | #5 AND #8 | 493
10 | #9 limited to 2010–2015 | 215
11 | #10 limited to English language | 214

Table A-3 Medication

Interface: OVID; Database: EMBASE

| Search | Results
1 | exp autism/ | 43068
2 | exp autism/dt [Drug Therapy] | 2497
3 | exp *autism/dt [Drug Therapy] | 1766
4 | exp central nervous system agents/ | 1386129
5 | exp *central nervous system agents/ | 734471
6 | exp *autism/ | 28323
7 | 5 and 6 | 1213
8 | 3 or 7 | 2307
9 | limit 8 to (english language and yr=“2010”) | 116