# Acronyms and Abbreviations

ABC: Aberrant Behavior Checklist
ADHD: attention deficit hyperactivity disorder
ADOS: Autism Diagnostic Observation Schedule
AHRQ: Agency For Healthcare Research And Quality
ASD: Autism Spectrum Disorder
ATEC: Autism Treatment Evaluation Checklist
BASC: Behavior Assessment System for Children
BMI: Body Mass Index
CARS: Childhood Autism Rating Scale
CBT: Cognitive Behavioral Therapy
CCC: Children’s Communication Checklist
CER: Comparative Effectiveness Review
CGAS: Children’s Global Assessment Scale
CGI: Clinical Global Impression
CI: Confidence Interval
CSBQ: Children’s Social Behavior Questionnaire
CTRS: Connor’s Teacher Rating Scales
CYBOCS: Children’s Yale-Brown Obsessive Compulsive Scale
DHA: Docosahexanoic Acid
DSM-IV: Diagnostic Statistical Manual - IV
EEG: Electroencephalogram
EOT: End of Treatment
EPS: Extrapyramidal symptoms
EVT: Expressive Vocabulary Test
ES: Effect Size
FDA: Food and Drug Administration
FFA: Free Fatty Acid
G: Group
GFCF: Gluten Free, Casein Free (Diet)
IQ: Intelligence Quotient
kg: Kilograms
KQ: Key Question
mg: Milligram
MPH: Methylphenidate
n: Number
NA: Not Applicable
ND: No Data
NR: Not Reported
ns: Not Significant
ODD: Oppositional Defiant Disorder
OT/SI: Occupational Therapy With Sensory Integration
PDD: Pervasive Developmental Disorder
PDD-BI: Pervasive Development Disorder Behavioral Inventory
PDD-NOS: Pervasive Developmental Disorder – Not Otherwise Specified
PICOTS: Population, Intervention, Comparator, Outcome, Timing, Setting
PLS: Preschool Language Scale
PPVT: Peabody Picture Vocabulary Test
RBS: Repetitive Behavior Scale
RCT: Randomized, Controlled Trial
ROB: Risk of Bias
RR: Risk Ratio
RUPP: Research Units on Pediatric Psychopharmacology
SD: Standard Deviation
SNAP-IV: Swanson Nolan and Pelham rating scale
SOE: Strength of Evidence
SRS: Social Responsiveness Scale
SSRI: Selective Serotonin Reuptake Inhibitors
TEACCH: Treatment and Education of Autistic and Communication related handicapped CHildren
TEP: Technical Expert Panel
VABS: Vineland Adaptive Behavior Scales