# References

1 Langa KM, Larson EB, Crimmins EM, . A Comparison of the Prevalence of Dementia in the United States in 2000 and 2012. JAMA Internal Medicine 2016 Nov 21, 2016 doi: 10.1001/jamainternmed.2016.6807. PMID: 27893041.27893041
2 Satizabal CL, Beiser AS, Chouraki V, . Incidence of Dementia over Three Decades in the Framingham Heart Study. N Engl J Med. 2016 Feb 11;374(6):523–32. doi: 10.1056/NEJMoa1504327. PMID: 26863354.26863354
3 Plassman BL, Langa KM, Fisher GG, . Prevalence of cognitive impairment without dementia in the United States. Ann Intern Med. 2008 Mar 18;148(6):427–34. PMID: 18347351.18347351
4 Williams JW, Plassman BL, Burke J, . Preventing Alzheimer’s Disease and Cognitive Decline (Prepaired by the Duke Evidence-based Practice Center Under Contract No. HHSA 290–2007-10066-I). Rockville, MD: 2010.
5 Kelley A, McGarry K, Gorges R, . The Burden of Health Care Costs for Patients With Dementia in the Last 5 Years of LifeBurden of Health Care Costs for Patients With Dementia. Ann Intern Med. 2015;Published online 27 October 2015 10.7326/M15-0381.
6 McKhann GM, Knopman DS, Chertkow H, . The diagnosis of dementia due to Alzheimer’s disease: recommendations from the National Institute on Aging-Alzheimer’s Association workgroups on diagnostic guidelines for Alzheimer’s disease. Alzheimer’s & Dementia. 2011 May;7(3):263–9. doi: http://dx.doi.org/10.1016/j.jalz.2011.03.005. PMID: 21514250.21514250
7 Jack CR, Jr., Albert MS, Knopman DS, . Introduction to the recommendations from the National Institute on Aging-Alzheimer’s Association workgroups on diagnostic guidelines for Alzheimer’s disease. Alzheimer’s & Dementia. 2011 May 2011;7(3):257–62. doi: 10.1016/j.jalz.2011.03.004. PMID: 21514247.21514247
8 American Psychiatric Association. Neurocognitive Disorders. Diagnostic and Statistical Manual of Mental Disorders, Fifth Edition. Arlington, VA: American Psychiatric Association; 2013.
9 Golomb J, Kluger A, Ferris SH. Mild cognitive impairment: historical development and summary of research. Dialogues Clin Neurosci. 2004 Dec;6(4):351–67. PMID: 22034453.22034453
10 Cooper C, Sommerlad A, Lyketsos CG, . Modifiable predictors of dementia in mild cognitive impairment: a systematic review and meta-analysis. American Journal of Psychiatry. 2015 Apr;172(4):323–34. doi: http://dx.doi.org/10.1176/appi.ajp.2014.14070878. PMID: 25698435.25698435
11 Petersen RC. Mild cognitive impairment as a diagnostic entity. Journal of Internal Medicine. 2004 Sep;256(3):183–94. PMID: 15324362.15324362
12 IOM (Institute of Medicine). Cognitive aging: progress in understanding and opportunities for action. Washington, DC: The National Academies Press; 2015.
13 Williams JW, Plassman BL, Burke J, . Preventing Alzheimer’s disease and cognitive decline. Evidence Report/Technology Assessment. 2010 Apr(193):1–727. PMID: 21500874.21500874
14 Solomon A, Mangialasche F, Richard E, . Advances in the prevention of Alzheimer’s disease and dementia. Journal of Internal Medicine. 2014;275(3):229–50. PMID: 24605807.24605807
15 National Institutes of Health. Cognitive and Emotional Health Project: The Healthy Brain. 2016. http://trans.nih.gov/CEHP/hbpcog-list.htm. Accessed on August 26 2016.
16 Lampit A, Valenzuela M, Gates NJ. Computerized Cognitive Training Is Beneficial for Older Adults. J Am Geriatr Soc. 2015 Dec 2015;63(12):2610–2. doi: 10.1111/jgs.13825. PMID: 26662712.26662712
17 Viswanathan M, Ansari M, Berkman N, . Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Agency for Healthcare Research and Quality; March 2012. Methods Guide for Comparative Effectiveness Reviews. AHRQ Publication No 12-EHC047-EF. Available at http://effectivehealthcare.ahrq.gov/.
18 Stein J, Luppa M, Brahler E, . The assessment of changes in cognitive functioning: reliable change indices for neuropsychological instruments in the elderly - a systematic review. Dementia & Geriatric Cognitive Disorders. 2010;29(3):275–86. doi: http://dx.doi.org/10.1159/000289779. PMID: 20375509.20375509
19 Bagos PG. Meta-anbalysis in Stata using gllamm. Res Synth Methods. 2015 Dec 2015;6(4):310–32.26612788
20 Fu R, Gartlehner G, Grant M, . Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. Journal of Clinical Epidemiology. 2011 Nov;64(11):1187–97. PMID: 21477993.21477993
21 Berkman ND, Lohr KN, Ansari M, . Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol. 2015 Nov;68(11):1312–24. doi: 10.1016/j.jclinepi.2014.11.023. Epub 2014 Dec 20. PMID: 2572157025721570
22 Atkins D, Chang S, Gartlehner G, . Assessing the applicability of studies when comparing medical interventions. Agency for Healthcare Research and Quality; January 2011. Methods Guide for Comparative Effectiveness Reviews. AHRQ Publication No 11-EHC019-EF. Available at http://effectivehealthcare.ahrq.gov/.
23 Ratner E, Atkinson D. Why Cognitive Training and Brain Games Will Not Prevent or Forestall Dementia. J Amer Geriatr Soc. 2015 Dec 2015;63(12):2612–4. doi: 10.1111/jgs.1_13825. PMID: 26660360.26660360
24 Simons DJ, Boot WR, Charness N, . Do “Brain-Training” Programs Work? Psychol Sci Public Interest. 2016 Oct 2017;17(3):103–86. doi: 10.1177/1529100616661983. PMID: 27697851.27697851
25 Ball K, Berch DB, Helmers KF, . Effects of cognitive training interventions with older adults: a randomized controlled trial. JAMA. 2002 Nov 13;288(18):2271–81. PMID: 12425704.12425704
26 Willis SL, Tennstedt SL, Marsiske M, . Long-term effects of cognitive training on everyday functional outcomes in older adults. JAMA. 2006 Dec 20;296(23):2805–14. PMID: 17179457.17179457
27 Rebok GW, Ball K, Guey LT, . Ten-year effects of the advanced cognitive training for independent and vital elderly cognitive training trial on cognition and everyday functioning in older adults. Journal of the American Geriatrics Society. 2014 Jan;62(1):16–24. doi: http://dx.doi.org/10.1111/jgs.12607. PMID: 24417410.24417410
28 Unverzagt FW, Guey LT, Jones RN, . ACTIVE cognitive training and rates of incident dementia. J Int Neuropsychol Soc. 2012 Jul;18(4):669–77. doi: 10.1017/s1355617711001470. PMID: 22400989.22400989
29 Jobe JB, Smith DM, Ball K, . ACTIVE: a cognitive intervention trial to promote independence in older adults. Control Clin Trials. 2001 Aug;22(4):453–79. PMID: 11514044.11514044
30 Ball K, Edwards JD, Ross LA, . Cognitive training decreases motor vehicle collision involvement of older drivers. J Amer Geriatr Soc. 2010 Nov 2010;58(11):2107–13. doi: 10.1111/j.1532-5415.2010.03138.x. PMID: 21054291.21054291
31 Edwards JD, delahunt PB, Mahncke HW. Cognitive Speed of Procession Training Delays Driving Cessation. J Gerontol A Biol Sci Med Sci. 2009 Dec 2009;64(12):1262–7. doi: 10.1093/gerona/glp131. PMID: 19726665.19726665
32 Gallo JJ, R. BH, Morales KH, . Depression, cardiovascular disease, diabetes, and 2-year mortality among older primary care patients. Am J Geriatr Psychiatry; 2005. p. 748–55. PMID: 1616640316166403
33 Wolinsky FD, Vander Weg MW, Martin R, . The Effect of Speed-of-Processing Training on Depressive Symptoms in ACTIVE. Journal of Gerontology: Medical Sciences. 2009 Jan 30, 2009;64A(4):468–72. doi: doi:10.1093/gerona/gln044. PMID: 1918171919181719
34 Prindle JJ, McArdle JJ. How representative is the ACTIVE sample? A statistical comparison of the ACTIVE sample and the HRS sample. J of Aging and Health. 2013 Dec 2013;25(8S):85S–102S. doi: 10.1177/0898264313497795. PMID: 2438564124385641
35 The University of Michigan Health and Retirement Study. The University of Michigan Health and Retirement Study (HRS). 2016.
36 Cook SE, Marsiske M, Thomas KR, . Identification of Mild Cognitive Impairment in ACTIVE: Algorithmic Classification and Stability. J Int Neuropsychol Soc. 2013 Jan 2013;9(1):73–87. doi: 10.1017/S1355617712000938. PMID: 2309521823095218
37 Unverzagt FW, Kasten L, Johnson KE, . Effect of memory impairment on training outcomes in ACTIVE. Journal of the International Neuropsychological Society. 2007 Nov;13(6):953–60. PMID: 17942013.17942013
38 Edwards JD, Wadley VG, Myers R, . Transfer of a speed of processing intervention to near and far cognitive functions. Gerontology. 2002;48:329–40. doi: 10.1159/000065259. PMID: 1216980112169801
39 Edwards JD, Wadley VG, Vance DE, . The impact of speed of processing training on cognitive and everyday performance. Aging & Mental Health. 2005;9:262–71. doi: 10.1080/13607860412331336788. PMID: 1601928016019280
40 Duff K. Evidence-Based Indicators of Neuropsychological Change in the Individual Patient: Relevant Concepts and Methods. Archives of Clinical Neuropsychology. 2012 May 2012;27(3):248–61. doi: 10.1093/arclin/acr120. PMID: 22382384.22382384
41 Pedraza O, Smith GE, Ivnik RJ, . Reliable change on the Dementia Rating Scale. J Int Neuropsychol Soc. 2007 Jul 2007;13(4):716–20. PMID: 17521486.17521486
42 Miller KJ, Dye RV, Kim J, . Effect of a computerized brain exercise program on cognitive performance in older adults. American Journal of Geriatric Psychiatry. 2013 Jul;21(7):655–63. doi: http://dx.doi.org/10.1016/j.jagp.2013.01.077. PMID: 23602310.23602310
43 Klusmann V, Evers A, Schwarzer R, . Complex mental and physical activity in older women and cognitive performance: a 6-month randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2010 Jun;65(6):680–8. doi: 10.1093/gerona/glq053. PMID: 20418350.20418350
44 Carretti B, Borella E, Zavagnin M, . Gains in language comprehension relating to working memory training in healthy older adults. Int J Geriatr Psychiatry. 2013 May;28(5):539–46. doi: 10.1002/gps.3859. PMID: 22821686.22821686
45 Rapp S, Brenes G, Marsh AP. Memory enhancement training for older adults with mild cognitive impairment: a preliminary study. Aging & Mental Health. 2002 Feb;6(1):5–11. PMID: 11827617.11827617
46 Herrera C, Chambon C, Michel BF, . Positive effects of computer-based cognitive training in adults with mild cognitive impairment. Neuropsychologia. 2012 Jul;50(8):1871–81. doi: http://dx.doi.org/10.1016/j.neuropsychologia.2012.04.012. PMID: 22525705.22525705
47 Wolinsky FD, Vander Weg MW, Howren MB, . A randomized controlled trial of cognitive training using a visual speed of processing intervention in middle aged and older adults. PLoS ONE [Electronic Resource]. 2013;8(5):e61624. doi: http://dx.doi.org/10.1371/journal.pone.0061624. PMID: 23650501.23650501
48 Buschert VC, Giegling I, Teipel SJ, . Long-term observation of a multicomponent cognitive intervention in mild cognitive impairment. Journal of Clinical Psychiatry. 2012 Dec;73(12):e1492–8. doi: http://dx.doi.org/10.4088/JCP.11m07270. PMID: 23290333.23290333
49 Forster S, Buschert VC, Teipel SJ, . Effects of a 6-month cognitive intervention on brain metabolism in patients with amnestic MCI and mild Alzheimer’s disease. Journal of Alzheimer’s Disease. 2011;26 Suppl 3:337–48. doi: http://dx.doi.org/10.3233/JAD-2011-0025. PMID: 21971473.21971473
50 Kwok TC, Bai X, Li JC, . Effectiveness of cognitive training in Chinese older people with subjective cognitive complaints: a randomized placebo-controlled trial. International Journal of Geriatric Psychiatry. 2013 Feb;28(2):208–15. doi: http://dx.doi.org/10.1002/gps.3812. PMID: 22528470.22528470
51 Vidovich MR, Lautenschlager NT, Flicker L, . The PACE study: A randomized clinical trial of cognitive activity strategy training for older people with mild cognitive impairment. American Journal of Geriatric Psychiatry. 2015 01 Apr;23(4):360–72. doi :http://dx.doi.org/10.1016/j.jagp.2014.04.002. PMID: 2014736543.24801607
52 Stine-Morrow EA, Payne BR, Roberts BW, . Training versus engagement as paths to cognitive enrichment with aging. Psychology & Aging. 2014 Dec;29(4):891–906. doi: http://dx.doi.org/10.1037/a0038244. PMID: 25402337.25402337
53 Buchman AS, Boyle PA, Yu L, . Total daily physical activity and the risk of AD and cognitive decline in older adults. Neurology. . 2012 2012/4/24;78(17):1323–9. 10.1212/WNL.0b013e3182535d35. PMID: 2251710822517108
54 Antunes HK, De Mello MT, Santos-Galduroz RF, . Effects of a physical fitness program on memory and blood viscosity in sedentary elderly men. Braz J Med Biol Res. 2015 Sep;48(9):805–12. doi: 10.1590/1414-431X20154529. PMID: 26222648.26222648
55 Baker LD, Frank LL, Foster-Schubert K, . Aerobic exercise improves cognition for older adults with glucose intolerance, a risk factor for Alzheimer’s disease. J Alzheimers Dis. 2010;22(2):569–79. doi: 10.3233/JAD-2010-100768. PMID: 20847403.20847403
56 Baker LD, Frank LL, Foster-Schubert K, . Effects of aerobic exercise on mild cognitive impairment: a controlled trial. Arch Neurol. 2010 Jan;67(1):71–9. doi: 10.1001/archneurol.2009.307. PMID: 20065132.20065132
57 Best JR, Chiu BK, Liang Hsu C, . Long-term effects of resistance exercise training on cognition and brain volume in older women: Results from a randomized controlled trial. Journal of the International Neuropsychological Society. 2015 Nov;21(10):745–56. doi: http://dx.doi.org/10.1017/S1355617715000673. PMID: 2015-53115-004.26581787
58 Blumenthal JA, Emery CF, Madden DJ, . Long-term effects of exercise on psychological functioning in older men and women. Journal of Gerontology. 1991 Nov;46(6):P352–61. PMID: 1940092.1940092
59 Bun S, Ikejima C, Kida J, . A combination of supplements may reduce the risk of Alzheimer’s disease in elderly Japanese with normal cognition. J Alzheimers Dis. 2015;45(1):15–25. doi: 10.3233/JAD-142232. PMID: 25524956.25524956
60 Cassilhas RC, Viana VA, Grassmann V, . The impact of resistance exercise on the cognitive function of the elderly. Med Sci Sports Exerc. 2007 Aug;39(8):1401–7. doi: 10.1249/mss.0b013e318060111f. PMID: 17762374.17762374
61 Colcombe SJ, Erickson KI, Scalf PE, . Aerobic exercise training increases brain volume in aging humans. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2006 Nov;61(11):1166–70. PMID: 17167157.17167157
62 Eggenberger P, Schumacher V, Angst M, . Does multicomponent physical exercise with simultaneous cognitive training boost cognitive performance in older adults? A 6-month randomized controlled trial with a 1-year follow-up. Clin Interv Aging. 2015 17 Aug;10:1335–49. 10.2147/CIA.S87732. PMID: 26316729.26316729
63 Erickson KI, Voss MW, Prakash RS, . Exercise training increases size of hippocampus and improves memory. Proceedings of the National Academy of Sciences of the United States of America. 2011 Feb 15;108(7):3017–22. doi: http://dx.doi.org/10.1073/pnas.1015950108. PMID: 21282661.21282661
64 Evers A, Klusmann V, Schwarzer R, . Improving cognition by adherence to physical or mental exercise: a moderated mediation analysis. Aging Ment Health. 2011 May;15(4):446–55. doi: 10.1080/13607863.2010.543657. PMID: 21500011.21500011
65 Ferreira L, Tanaka K, Santos-Galduroz RF, . Respiratory training as strategy to prevent cognitive decline in aging: a randomized controlled trial. Clin Interv Aging. 2015 20 Mar;10:593–603. 10.2147/CIA.S79560. PMID: 25848235.25848235
66 Fiatarone Singh MA, Gates N, Saigal N, . The Study of Mental and Resistance Training (SMART) study-resistance training and/or cognitive training in mild cognitive impairment: a randomized, double-blind, double-sham controlled trial. J Am Med Dir Assoc. 2014 Dec;15(12):873–80. doi: 10.1016/j.jamda.2014.09.010. PMID: 25444575.25444575
67 Hildreth KL, Van Pelt RE, Moreau KL, . Effects of pioglitazone or exercise in older adults with mild cognitive impairment and insulin resistance: a pilot study. Dement Geriatr Cogn Dis Extra. 2015 Jan–Apr;5(1):51–63. 10.1159/000371509. PMID: 25852732.25852732
68 Hotting K, Reich B, Holzschneider K, . Differential cognitive effects of cycling versus stretching/coordination training in middle-aged adults. Health Psychol. 2012 Mar;31(2):145–55. doi: 10.1037/a0025371. PMID: 21895371.21895371
69 Komulainen P, Kivipelto M, Lakka T, . Exercise, fitness and cognition–A randomised controlled trial in older individuals: The DR’s EXTRA study. European Geriatric Medicine. 2010;1(5):266–72.
70 Kramer AF, Hahn S, Cohen NJ, . Ageing, fitness and neurocognitive function. Nature. 1999 Jul 29;400(6743):418–9. PMID: 10440369.10440369
71 Lachman ME, Neupert SD, Bertrand R, . The effects of strength training on memory in older adults. Journal of Aging & Physical Activity. 2006 Jan;14(1):59–73. PMID: 16648652.16648652
72 Lam LC, Chan WC, Leung T, . Would older adults with mild cognitive impairment adhere to and benefit from a structured lifestyle activity intervention to enhance cognition?: a cluster randomized controlled trial. PLoS One. 2015 31 Mar;10(3):e0118173. 10.1371/journal.pone.0118173. PMID: 25826620.25826620
73 Lam LC, Chau RC, Wong BM, . A 1-year randomized controlled trial comparing mind body exercise (Tai Chi) with stretching and toning exercise on cognitive function in older Chinese adults at risk of cognitive decline. J Am Med Dir Assoc. 2012 Jul;13(6):568 e15–20. doi: 10.1016/j.jamda.2012.03.008. PMID: 22579072.22579072
74 Lautenschlager NT, Cox KL, Flicker L, . Effect of physical activity on cognitive function in older adults at risk for Alzheimer disease: a randomized trial. JAMA. 2008 Sep 3;300(9):1027–37. doi: 10.1001/jama.300.9.1027. PMID: 18768414.18768414
75 Law LL, Barnett F, Yau MK, . Effects of functional tasks exercise on older adults with cognitive impairment at risk of Alzheimer’s disease: a randomised controlled trial. Age Ageing. 2014 Nov;43(6):813–20. doi: 10.1093/ageing/afu055. PMID: 24850540.24850540
76 Liu-Ambrose T, Donaldson MG, Ahamed Y, . Otago home-based strength and balance retraining improves executive functioning in older fallers: a randomized controlled trial. Journal of the American Geriatrics Society. 2008 Oct;56(10):1821–30. doi: http://dx.doi.org/10.1111/j.1532-5415.2008.01931.x. PMID: 18795987.18795987
77 Liu-Ambrose T, Nagamatsu LS, Graf P, . Resistance training and executive functions: a 12-month randomized controlled trial. Archives of Internal Medicine. 2010 Jan 25;170(2):170–8. doi: http://dx.doi.org/10.1001/archinternmed.2009.494. PMID: 20101012.20101012
78 Madden DJ, Blumenthal JA, Allen PA, . Improving aerobic capacity in healthy older adults does not necessarily lead to improved cognitive performance. Psychology & Aging. 1989 Sep;4(3):307–20. PMID: 2803624.2803624
79 Mortimer JA, Ding D, Borenstein AR, . Changes in brain volume and cognition in a randomized trial of exercise and social interaction in a community-based sample of non-demented Chinese elders. J Alzheimers Dis. 2012;30(4):757–66. doi: 10.3233/JAD-2012-120079. PMID: 22451320.22451320
80 Muscari A, Giannoni C, Pierpaoli L, . Chronic endurance exercise training prevents aging-related cognitive decline in healthy older adults: a randomized controlled trial. Int J Geriatr Psychiatry. 2010 Oct;25(10):1055–64. doi: 10.1002/gps.2462. PMID: 20033904.20033904
81 Nagamatsu LS, Chan A, Davis JC, . Physical activity improves verbal and spatial memory in older adults with probable mild cognitive impairment: a 6-month randomized controlled trial. J Aging Res. 2013;2013(861893):861893. doi: 10.1155/2013/861893. PMID: 23509628.23509628
82 Nagamatsu LS, Handy TC, Hsu CL, . Resistance training promotes cognitive and functional brain plasticity in seniors with probable mild cognitive impairment. Arch Intern Med. 2012 Apr 23;172(8):666–8. doi: 10.1001/archinternmed.2012.379. PMID: 22529236.22529236
83 Napoli N, Shah K, Waters DL, . Effect of weight loss, exercise, or both on cognition and quality of life in obese older adults. Am J Clin Nutr. 2014 Jul;100(1):189–98. doi: 10.3945/ajcn.113.082883. PMID: 24787497.24787497
84 Nguyen MH, Kruse A. A randomized controlled trial of Tai chi for balance, sleep quality and cognitive performance in elderly Vietnamese. Clin Interv Aging. 2012;7:185–90. doi: 10.2147/CIA.S32600. PMID: 22807627.22807627
85 Oken BS, Zajdel D, Kishiyama S, . Randomized, controlled, six-month trial of yoga in healthy seniors: effects on cognition and quality of life. Alternative Therapies in Health & Medicine. 2006 Jan–Feb;12(1):40–7. PMID: 16454146.16454146
86 Okumiya K, Matsubayashi K, Wada T, . Effects of exercise on neurobehavioral function in community-dwelling older people more than 75 years of age. Journal of the American Geriatrics Society. 1996 May;44(5):569–72. PMID: 8617907.8617907
87 Oswald WD, Gunzelmann T, Rupprecht R, . Differential effects of single versus combined cognitive and physical training with older adults: the SimA study in a 5-year perspective. European Journal of Ageing. 2006;3(4):179–92.28794762
88 Rosano C, Venkatraman VK, Guralnik J, . Psychomotor speed and functional brain MRI 2 years after completing a physical activity treatment. J Gerontol A Biol Sci Med Sci. 2010 Jun;65(6):639–47. doi: 10.1093/gerona/glq038. PMID: 20348185.20348185
89 Ruscheweyh R, Willemer C, Kruger K, . Physical activity and memory functions: an interventional study. Neurobiology of Aging. 2011 Jul;32(7):1304–19. doi: http://dx.doi.org/10.1016/j.neurobiolaging.2009.08.001. PMID: 19716631.19716631
90 Satoh M, Ogawa J, Tokita T, . The effects of physical exercise with music on cognitive function of elderly people: Mihama-Kiho project. PLoS One. 2014;9(4):e95230. doi: 10.1371/journal.pone.0095230. PMID: 24769624.24769624
91 Sink KM, Espeland MA, Castro CM, . Effect of a 24-Month Physical Activity Intervention vs. Health Education on Cognitive Outcomes in Sedentary Older Adults: The LIFE Randomized Trial. JAMA. 2015 Aug 25;314(8):781–90. doi: 10.1001/jama.2015.9617. PMID: 26305648.26305648
92 Smiley-Oyen AL, Lowry KA, Francois SJ, . Exercise, fitness, and neurocognitive function in older adults: the “selective improvement” and “cardiovascular fitness” hypotheses. Annals of Behavioral Medicine. 2008 Dec;36(3):280–91. doi: http://dx.doi.org/10.1007/s12160-008-9064-5. PMID: 18825471.18825471
93 Suzuki T, Shimada H, Makizako H, . A randomized controlled trial of multicomponent exercise in older adults with mild cognitive impairment. PLoS One. 2013;8(4):e61483. doi: 10.1371/journal.pone.0061483. PMID: 23585901.23585901
94 Suzuki T, Shimada H, Makizako H, . Effects of multicomponent exercise on cognitive function in older adults with amnestic mild cognitive impairment: a randomized controlled trial. BMC Neurol. 2012;12:128. doi: 10.1186/1471-2377-12-128. PMID: 23113898.23113898
95 Taylor-Piliae RE, Newell KA, Cherin R, . Effects of Tai Chi and Western exercise on physical and cognitive functioning in healthy community-dwelling older adults. J Aging Phys Act. 2010 Jul;18(3):261–79. PMID: 20651414.20651414
96 ten Brinke LF, Bolandzadeh N, Nagamatsu LS, . Aerobic exercise increases hippocampal volume in older women with probable mild cognitive impairment: a 6-month randomised controlled trial. Br J Sports Med. 2015 Feb;49(4):248–54. doi: 10.1136/bjsports-2013-093184. PMID: 24711660.24711660
97 van de Rest O, van der Zwaluw NL, Tieland M, . Effect of resistance-type exercise training with or without protein supplementation on cognitive functioning in frail and pre-frail elderly: secondary analysis of a randomized, double-blind, placebo-controlled trial. Mech Ageing Dev. 2014 Mar–Apr;136–137:85–93. 10.1016/j.mad.2013.12.005. PMID: 24374288.24374288
98 van Uffelen JG, Chinapaw MJ, van Mechelen W, . Walking or vitamin B for cognition in older adults with mild cognitive impairment? A randomised controlled trial. British Journal of Sports Medicine. 2008 May;42(5):344–51. doi: http://dx.doi.org/10.1136/bjsm.2007.044735. PMID: 18308888.18308888
99 Williams P, Lord SR. Effects of group exercise on cognitive functioning and mood in older women. Australian & New Zealand Journal of Public Health. 1997 Feb;21(1):45–52. PMID: 9141729.9141729
100 Williamson JD, Espeland M, Kritchevsky SB, . Changes in cognitive function in a randomized trial of physical activity: results of the lifestyle interventions and independence for elders pilot study. J Gerontol A Biol Sci Med Sci. 2009 Jun;64(6):688–94. doi: 10.1093/gerona/glp014. PMID: 19244157.19244157
101 Andreeva VA, Kesse-Guyot E, Barberger-Gateau P, . Cognitive function after supplementation with B vitamins and long-chain omega-3 fatty acids: ancillary findings from the SU.FOL.OM3 randomized trial. Am J Clin Nutr. 2011 Jul;94(1):278–86. doi: 10.3945/ajcn.110.006320. PMID: 21593490.21593490
102 Chew EY, Clemons TE, Agron E, . Effect of Omega-3 Fatty Acids, Lutein/Zeaxanthin, or Other Nutrient Supplementation on Cognitive Function: The AREDS2 Randomized Clinical Trial. JAMA. 2015 Aug 25;314(8):791–801. doi: 10.1001/jama.2015.9677. PMID: 26305649.26305649
103 Dangour AD, Allen E, Elbourne D, . Effect of 2-y n-3 long-chain polyunsaturated fatty acid supplementation on cognitive function in older people: a randomized, double-blind, controlled trial. American Journal of Clinical Nutrition. 2010 Jun;91(6):1725–32. doi: http://dx.doi.org/10.3945/ajcn.2009.29121. PMID: 20410089.20410089
104 DeKosky ST, Williamson JD, Fitzpatrick AL, . Ginkgo biloba for prevention of dementia: a randomized controlled trial.[Erratum appears in JAMA. 2008 Dec 17;300(23):2730]. JAMA. 2008 Nov 19;300(19):2253–62. doi: http://dx.doi.org/10.1001/jama.2008.683. PMID: 19017911.19017911
105 Dodge HH, Zitzelberger T, Oken BS, . A randomized placebo-controlled trial of Ginkgo biloba for the prevention of cognitive decline. Neurology. 2008 May 6;70(19 Pt 2):1809–17. doi: http://dx.doi.org/10.1212/01.wnl.0000303814.13509.db. PMID: 18305231.18305231
106 Gavrilova SI, Preuss UW, Wong JW, . Efficacy and safety of Ginkgo biloba extract EGb 761 in mild cognitive impairment with neuropsychiatric symptoms: a randomized, placebo-controlled, double-blind, multi-center trial. International Journal of Geriatric Psychiatry. 2014 Oct;29(10):1087–95. doi: http://dx.doi.org/10.1002/gps.4103. PMID: 24633934.24633934
107 Geleijnse JM, Giltay EJ, Kromhout D. Effects of n-3 fatty acids on cognitive decline: a randomized, double-blind, placebo-controlled trial in stable myocardial infarction patients. Alzheimer’s & Dementia. 2012 Jul;8(4):278–87. doi: http://dx.doi.org/10.1016/j.jalz.2011.06.002. PMID: 21967845.21967845
108 Lee LK, Shahar S, Chin AV, . Docosahexaenoic acid-concentrated fish oil supplementation in subjects with mild cognitive impairment (MCI): a 12-month randomised, double-blind, placebo-controlled trial. Psychopharmacology. 2013 Feb;225(3):605–12. doi: http://dx.doi.org/10.1007/s00213-012-2848-0. PMID: 22932777.22932777
109 Lewis JE, Melillo AB, Tiozzo E, . A double-blind, randomized clinical trial of dietary supplementation on cognitive and immune functioning in healthy older adults.[Erratum appears in BMC Complement Altern Med. 2014;14:332]. BMC Complementary & Alternative Medicine. 2014;14:43. doi: http://dx.doi.org/10.1186/1472-6882-14-43. PMID: 24495355.24495355
110 Maki PM, Rubin LH, Fornelli D, . Effects of botanicals and combined hormone therapy on cognition in postmenopausal women. Menopause. 2009 Nov–Dec;16(6):1167–77. 10.1097/gme.0b013e3181ace484. PMID: 19590458.19590458
111 Schiepers OJ, de Groot RH, van Boxtel MP, . Consuming functional foods enriched with plant sterol or stanol esters for 85 weeks does not affect neurocognitive functioning or mood in statin-treated hypercholesterolemic individuals. Journal of Nutrition. 2009 Jul;139(7):1368–73. doi: http://dx.doi.org/10.3945/jn.108.103721. PMID: 19458031.19458031
112 Sinn N, Milte CM, Street SJ, . Effects of n-3 fatty acids, EPA v. DHA, on depressive symptoms, quality of life, memory and executive function in older adults with mild cognitive impairment: a 6-month randomised controlled trial. British Journal of Nutrition. 2012 Jun;107(11):1682–93. doi: http://dx.doi.org/10.1017/S0007114511004788. PMID: 21929835.21929835
113 Snitz BE, O’Meara ES, Carlson MC, . Ginkgo biloba for preventing cognitive decline in older adults: a randomized trial. JAMA. 2009 Dec 23;302(24):2663–70. doi: http://dx.doi.org/10.1001/jama.2009.1913. PMID: 20040554.20040554
114 Stonehouse W, Conlon CA, Podd J, . DHA supplementation improved both memory and reaction time in healthy young adults: a randomized controlled trial. American Journal of Clinical Nutrition. 2013 May;97(5):1134–43. doi: http://dx.doi.org/10.3945/ajcn.112.053371. PMID: 23515006.23515006
115 van de Rest O, Geleijnse JM, Kok FJ, . Effect of fish oil on cognitive performance in older subjects: a randomized, controlled trial. Neurology. 2008 Aug 5;71(6):430–8. doi: http://dx.doi.org/10.1212/01.wnl.0000324268.45138.86. PMID: 18678826.18678826
116 Vellas B, Coley N, Ousset PJ, . Long-term use of standardised Ginkgo biloba extract for the prevention of Alzheimer’s disease (GuidAge): a randomised placebo-controlled trial. Lancet Neurology. 2012 Oct;11(10):851–9. doi: http://dx.doi.org/10.1016/S1474-4422(12)70206-5. PMID: 22959217.22959217
117 Witte AV, Kerti L, Hermannstadter HM, . Long-chain omega-3 fatty acids improve brain function and structure in older adults. Cerebral Cortex. 2014 Nov;24(11):3059–68. doi: http://dx.doi.org/10.1093/cercor/bht163. PMID: 23796946.23796946
118 Witte AV, Kerti L, Margulies DS, . Effects of resveratrol on memory performance, hippocampal functional connectivity, and glucose metabolism in healthy older adults. Journal of Neuroscience. 2014 Jun 4;34(23):7862–70. doi: http://dx.doi.org/10.1523/JNEUROSCI.0385-14.2014. PMID: 24899709.24899709
119 Yurko-Mauro K, McCarthy D, Rom D, . Beneficial effects of docosahexaenoic acid on cognition in age-related cognitive decline. Alzheimer’s & Dementia. 2010 Nov;6(6):456–64. doi: http://dx.doi.org/10.1016/j.jalz.2010.01.013. PMID: 20434961.20434961
120 Cukierman-Yaffe T, Bosch J, Diaz R, . Effects of basal insulin glargine and omega-3 fatty acid on cognitive decline and probable cognitive impairment in people with dysglycaemia: a substudy of the ORIGIN trial. Lancet Diabetes Endocrinol. 2014 Jul;2(7):562–72. doi: 10.1016/S2213-8587(14)70062-2. PMID: 24898834.24898834
121 Strike SC, Carlisle A, Gibson EL, . A High Omega-3 Fatty Acid Multinutrient Supplement Benefits Cognition and Mobility in Older Women: A Randomized, Double-blind, Placebo-controlled Pilot Study. J Gerontol A Biol Sci Med Sci. 2016 Feb;71(2):236–42. doi: 10.1093/gerona/glv109. PMID: 26265727.26265727
122 Scherrer B, Andrieu S, Ousset PJ, . Analysing Time to Event Data in Dementia Prevention Trials: The Example of the GuidAge Study of EGb761. Journal of Nutrition, Health & Aging. 2015 Dec;19(10):1009–11. doi: http://dx.doi.org/10.1007/s12603-015-0582-0. PMID: 26624212.26624212
123 Mahmoudi MJ, Hedayat M, Sharifi F, . Effect of low dose omega-3 poly unsaturated fatty acids on cognitive status among older people: a double-blind randomized placebo-controlled study. J Diabetes Metab Disord. 2014 Feb 07;13(1):34. doi: 10.1186/2251-6581-13-34. PMID: 24507770.24507770
124 Boespflug EL, McNamara RK, Eliassen JC, . Fish Oil Supplementation Increases Event-Related Posterior Cingulate Activation in Older Adults with Subjective Memory Impairment. J Nutr Health Aging. 2016 Feb;20(2):161–9. doi: 10.1007/s12603-015-0609-6. PMID: 26812512.26812512
125 Brinkworth GD, Buckley JD, Noakes M, . Long-term effects of a very low-carbohydrate diet and a low-fat diet on mood and cognitive function. Arch Intern Med. 2009 Nov 9;169(20):1873–80. doi: 10.1001/archinternmed.2009.329. PMID: 19901139.19901139
126 Martin CK, Anton SD, Han H, . Examination of cognitive function during six months of calorie restriction: results of a randomized controlled trial. Rejuvenation Res. 2007 Jun;10(2):179–90. doi: 10.1089/rej.2006.0502. PMID: 17518698.17518698
127 Martinez-Lapiscina EH, Clavero P, Toledo E, . Mediterranean diet improves cognition: the PREDIMED-NAVARRA randomised trial. J Neurol Neurosurg Psychiatry. 2013 Dec;84(12):1318–25. doi: 10.1136/jnnp-2012-304792. PMID: 23670794.23670794
128 Martinez-Lapiscina EH, Clavero P, Toledo E, . Virgin olive oil supplementation and long-term cognition: the PREDIMED-NAVARRA randomized, trial. J Nutr Health Aging. 2013;17(6):544–52. doi: 10.1007/s12603-013-0027-6. PMID: 23732551.23732551
129 Valls-Pedret C, Sala-Vila A, Serra-Mir M, . Mediterranean Diet and Age-Related Cognitive Decline: A Randomized Clinical Trial. JAMA Intern Med. 2015 Jul;175(7):1094–103. doi: 10.1001/jamainternmed.2015.1668. PMID: 25961184.25961184
130 van der Zwaluw NL, van de Rest O, Tieland M, . The impact of protein supplementation on cognitive performance in frail elderly. Eur J Nutr. 2014 Apr;53(3):803–12. doi: 10.1007/s00394-013-0584-9. PMID: 24045855.24045855
131 Wouters-Wesseling W, Wagenaar LW, Rozendaal M, . Effect of an enriched drink on cognitive function in frail elderly persons. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2005 Feb;60(2):265–70. PMID: 15814873.15814873
132 Carlson MC, Saczynski JS, Rebok GW, . Exploring the effects of an “everyday” activity program on executive function and memory in older adults: Experience Corps. Gerontologist. 2008 Dec;48(6):793–801. PMID: 19139252.19139252
133 Clare L, Nelis SM, Jones IR, . The Agewell trial: a pilot randomised controlled trial of a behaviour change intervention to promote healthy ageing and reduce risk of dementia in later life. BMC Psychiatry. 2015;15:25. doi: 10.1186/s12888-015-0402-4. PMID: 25880911.25880911
134 Clark F, Jackson J, Carlson M, . Effectiveness of a lifestyle intervention in promoting the well-being of independently living older people: results of the Well Elderly 2 Randomised Controlled Trial. J Epidemiol Community Health. 2012 Sep;66(9):782–90. doi: 10.1136/jech.2009.099754. PMID: 21636614.21636614
135 Hars M, Herrmann FR, Gold G, . Effect of music-based multitask training on cognition and mood in older adults. Age Ageing. 2014 Mar;43(2):196–200. doi: 10.1093/ageing/aft163. PMID: 24212920.24212920
136 Johari SM, Shahar S, Ng TP, . A Preliminary Randomized Controlled Trial of Multifaceted Educational Intervention for Mild Cognitive Impairment Among Elderly Malays in Kuala Lumpur. International Journal of Gerontology. 2014 Jun;8(2):74–80. doi: 10.1016/j.ijge.2013.07.002. PMID: WOS:000339088200006.
137 Kobe T, Witte A, Schnelle A, . Combined omega-3 fatty acids, aerobic exercise and cognitive stimulation prevents decline in gray matter volume of the frontal, Parietal and cingulate cortex in patients with mild cognitive impairment. NeuroImage. 2016 01 May;131:226–38. doi: http://dx.doi.org/10.1016/j.neuroimage.2015.09.050. PMID: 607245692.26433119
138 Lee KS, Lee Y, Back JH, . Effects of a multidomain lifestyle modification on cognitive function in older adults: an eighteen-month community-based cluster randomized controlled trial. Psychother Psychosom. 2014;83(5):270–8. doi: 10.1159/000360820. PMID: 25116574.25116574
139 Lehtisalo J, Lindstrom J, Ngandu T, . Association of Long-Term Dietary Fat Intake, Exercise, and Weight with Later Cognitive Function in the Finnish Diabetes Prevention Study. Journal of Nutrition, Health & Aging. 2016 Feb;20(2):146–54. doi: http://dx.doi.org/10.1007/s12603-015-0565-1. PMID: 26812510.26812510
140 McDaniel MA, Binder EF, Bugg JM, . Effects of cognitive training with and without aerobic exercise on cognitively demanding everyday activities. Psychol Aging. 2014 Sep;29(3):717–30. doi: 10.1037/a0037363. PMID: 25244489.25244489
141 Moll van Charante EP, Richard E, Eurelings LS, . Effectiveness of a 6-year multidomain vascular care intervention to prevent dementia (preDIVA): A cluster-randomised controlled trial. The Lancet. 2016 Aug;388(10046):797–805. doi: http://dx.doi.org/10.1016/S0140-6736%2816%2930950-3.
142 Ngandu T, Lehtisalo J, Solomon A, . A 2 year multidomain intervention of diet, exercise, cognitive training, and vascular risk monitoring versus control to prevent cognitive decline in at-risk elderly people (FINGER): a randomised controlled trial. Lancet. 2015 Jun 6;385(9984):2255–63. doi: 10.1016/S0140-6736(15)60461-5. PMID: 25771249.25771249
143 Tesky VA, Thiel C, Banzer W, . Effects of a Group Program to Increase Cognitive Performance Through Cognitively Stimulating Leisure Activities in Healthy Older Subjects. GeroPsych. 2011 01 Jun;24(2):83–92. 10.1024/1662-9647/a000035. PMID: 2011313185.
144 Yesavage JA, Friedman L, Ashford JW, . Acetylcholinesterase inhibitor in combination with cognitive training in older adults. J Gerontol B Psychol Sci Soc Sci. 2008 Sep;63(5):P288-94. PMID: 18818443.18818443
145 Alhola P, Tuomisto H, Saarinen R, . Estrogen + progestin therapy and cognition: a randomized placebo-controlled double-blind study. J Obstet Gynaecol Res. 2010 Aug;36(4):796–802. doi: 10.1111/j.1447-0756.2010.01214.x. PMID: 20666948.20666948
146 Binder EF, Schechtman KB, Birge SJ, . Effects of hormone replacement therapy on cognitive performance in elderly women. Maturitas. 2001 Apr 20;38(2):137–46. PMID: 11306202.11306202
147 Casini ML, Marelli G, Papaleo E, . Psychological assessment of the effects of treatment with phytoestrogens on postmenopausal women: a randomized, double-blind, crossover, placebo-controlled study. Fertil Steril. 2006 Apr;85(4):972–8. doi: 10.1016/j.fertnstert.2005.09.048. PMID: 16580383.16580383
148 Cherrier MM, Anderson K, Shofer J, . Testosterone treatment of men with mild cognitive impairment and low testosterone levels. Am J Alzheimers Dis Other Demen. 2015 Jun;30(4):421–30. doi: 10.1177/1533317514556874. PMID: 25392187.25392187
149 Coker LH, Hogan PE, Bryan NR, . Postmenopausal hormone therapy and subclinical cerebrovascular disease: the WHIMS-MRI Study. Neurology. 2009 Jan 13;72(2):125–34. doi: 10.1212/01.wnl.0000339036.88842.9e. PMID: 19139363.19139363
150 Davison SL, Bell RJ, Robinson PJ, . Continuous-combined oral estradiol/drospirenone has no detrimental effect on cognitive performance and improves estrogen deficiency symptoms in early postmenopausal women: a randomized placebo-controlled trial. Menopause. 2013 Oct;20(10):1020–6. doi: 10.1097/GME.0b013e318287474f. PMID: 23591255.23591255
151 Espeland MA, Rapp SR, Shumaker SA, . Conjugated equine estrogens and global cognitive function in postmenopausal women: Women’s Health Initiative Memory Study. JAMA. 2004 Jun 23;291(24):2959–68. doi: 10.1001/jama.291.24.2959. PMID: 15213207.15213207
152 Espeland MA, Brunner RL, Hogan PE, . Long-term effects of conjugated equine estrogen therapies on domain-specific cognitive function: results from the Women’s Health Initiative study of cognitive aging extension. J Am Geriatr Soc. 2010 Jul;58(7):1263–71. doi: 10.1111/j.1532-5415.2010.02953.x. PMID: 20649689.20649689
153 Espeland MA, Shumaker SA, Leng I, . Long-term effects on cognitive function of postmenopausal hormone therapy prescribed to women aged 50 to 55 years. JAMA Intern Med. 2013 Aug 12;173(15):1429–36. doi: 10.1001/jamainternmed.2013.7727. PMID: 23797469.23797469
154 Espeland MA, Shumaker SA, Limacher M, . Relative effects of tamoxifen, raloxifene, and conjugated equine estrogens on cognition. J Womens Health (Larchmt). 2010 Mar;19(3):371–9. doi: 10.1089/jwh.2009.1605. PMID: 20136553.20136553
155 Gleason CE, Carlsson CM, Barnet JH, . A preliminary study of the safety, feasibility and cognitive efficacy of soy isoflavone supplements in older men and women. Age Ageing. 2009 Jan;38(1):86–93. doi: 10.1093/ageing/afn227. PMID: 19054783.19054783
156 Gleason CE, Dowling NM, Wharton W, . Effects of Hormone Therapy on Cognition and Mood in Recently Postmenopausal Women: Findings from the Randomized, Controlled KEEPS-Cognitive and Affective Study. PLoS Med. 2015 Jun;12(6):e1001833; discussion e. doi: 10.1371/journal.pmed.1001833. PMID: 26035291.26035291
157 Gorenstein C, Renno J, Jr., Vieira Filho AH, . Estrogen replacement therapy and cognitive functions in healthy postmenopausal women: a randomized trial. Arch Womens Ment Health. 2011 Oct;14(5):367–73. doi: 10.1007/s00737-011-0230-6. PMID: 21732218.21732218
158 Grady D, Yaffe K, Kristof M, . Effect of postmenopausal hormone therapy on cognitive function: the Heart and Estrogen/progestin Replacement Study. Am J Med. 2002 Nov;113(7):543–8. PMID: 12459399.12459399
159 Henderson VW, St John JA, Hodis HN, . Long-term soy isoflavone supplementation and cognition in women: a randomized, controlled trial. Neurology. 2012 Jun 5;78(23):1841–8. doi: 10.1212/WNL.0b013e318258f822. PMID: 22665144.22665144
160 Henderson VW, St John JA, Hodis HN, . Cognitive effects of estradiol after menopause: A randomized trial of the timing hypothesis. Neurology. 2016 Aug 16;87(7):699–708. doi: 10.1212/wnl.0000000000002980. PMID: 27421538.27421538
161 Ho SC, Chan AS, Ho YP, . Effects of soy isoflavone supplementation on cognitive function in Chinese postmenopausal women: a double-blind, randomized, controlled trial. Menopause. 2007 May–Jun;14(3 Pt 1):489–99. 10.1097/GME.0b013e31802c4f4f. PMID: 17308499.17308499
162 Howes JB, Bray K, Lorenz L, . The effects of dietary supplementation with isoflavones from red clover on cognitive function in postmenopausal women. Climacteric. 2004 Mar;7(1):70–7. PMID: 15259285.15259285
163 Kantarci K, Lowe VJ, Lesnick TG, . Early postmenopausal transdermal 17beta-estradiol therapy and amyloid-beta deposition. Journal of Alzheimer’s Disease. 2016;53(2):547–56. doi: http://dx.doi.org/10.3233/JAD-160258.
164 Kato-Kataoka A, Sakai M, Ebina R, . Soybean-derived phosphatidylserine improves memory function of the elderly Japanese subjects with memory complaints. J Clin Biochem Nutr. 2010 Nov;47(3):246–55. doi: 10.3164/jcbn.10-62. PMID: 21103034.21103034
165 Kenny AM, Bellantonio S, Gruman CA, . Effects of transdermal testosterone on cognitive function and health perception in older men with low bioavailable testosterone levels. J Gerontol A Biol Sci Med Sci. 2002 May;57(5):M321–5. PMID: 11983727.11983727
166 Kreijkamp-Kaspers S, Kok L, Grobbee DE, . Effect of soy protein containing isoflavones on cognitive function, bone mineral density, and plasma lipids in postmenopausal women: a randomized controlled trial. Jama. 2004 Jul 7;292(1):65–74. doi: 10.1001/jama.292.1.65. PMID: 15238592.15238592
167 Kritz-Silverstein D, Von Muhlen D, Barrett-Connor E, . Isoflavones and cognitive function in older women: the SOy and Postmenopausal Health In Aging (SOPHIA) Study. Menopause. 2003 May–Jun;10(3):196–202. PMID: 12792289.12792289
168 Kritz-Silverstein D, von Muhlen D, Laughlin GA, . Effects of dehydroepiandrosterone supplementation on cognitive function and quality of life: the DHEA and Well-Ness (DAWN) Trial. J Am Geriatr Soc. 2008 Jul;56(7):1292–8. doi: 10.1111/j.1532-5415.2008.01768.x. PMID: 18482290.18482290
169 Legault C, Maki PM, Resnick SM, . Effects of tamoxifen and raloxifene on memory and other cognitive abilities: cognition in the study of tamoxifen and raloxifene. J Clin Oncol. 2009 Nov 1;27(31):5144–52. doi: 10.1200/JCO.2008.21.0716. PMID: 19770382.19770382
170 Moller MC, Bartfai AB, Radestad AF. Effects of testosterone and estrogen replacement on memory function. Menopause. 2010 Sep–Oct;17(5):983–9. 10.1097/gme.0b013e3181dc2e40. PMID: 20555288.20555288
171 Moller MC, Radestad AF, von Schoultz B, . Effect of estrogen and testosterone replacement therapy on cognitive fatigue. Gynecol Endocrinol. 2013 Feb;29(2):173–6. doi: 10.3109/09513590.2012.730568. PMID: 23095007.23095007
172 Nickelsen T, Lufkin EG, Riggs BL, . Raloxifene hydrochloride, a selective estrogen receptor modulator: safety assessment of effects on cognitive function and mood in postmenopausal women. Psychoneuroendocrinology. 1999 Jan;24(1):115–28. PMID: 10098223.10098223
173 Pan HA, Wang ST, Pai MC, . Cognitive function variations in postmenopausal women treated with continuous, combined HRT or tibolone. A comparison. J Reprod Med. 2003 May;48(5):375–80. PMID: 12815913.12815913
174 Pefanco MA, Kenny AM, Kaplan RF, . The effect of 3-year treatment with 0.25 mg/day of micronized 17beta-estradiol on cognitive function in older postmenopausal women. J Am Geriatr Soc. 2007 Mar;55(3):426–31. doi: 10.1111/j.1532-5415.2007.01085.x. PMID: 17341247.17341247
175 Rapp SR, Espeland MA, Shumaker SA, . Effect of estrogen plus progestin on global cognitive function in postmenopausal women: the Women’s Health Initiative Memory Study: a randomized controlled trial. Jama. 2003 May 28;289(20):2663–72. doi: 10.1001/jama.289.20.2663. PMID: 12771113.12771113
176 Rasgon NL, Geist CL, Kenna HA, . Prospective randomized trial to assess effects of continuing hormone therapy on cerebral function in postmenopausal women at risk for dementia. PLoS One. 2014;9(3):e89095. doi: 10.1371/journal.pone.0089095. PMID: 24622517.24622517
177 Resnick SM, Espeland MA, An Y, . Effects of conjugated equine estrogens on cognition and affect in postmenopausal women with prior hysterectomy. J Clin Endocrinol Metab. 2009 Nov;94(11):4152–61. doi: 10.1210/jc.2009-1340. PMID: 19850684.19850684
178 Resnick SM, Espeland MA, Jaramillo SA, . Postmenopausal hormone therapy and regional brain volumes: the WHIMS-MRI Study. Neurology. 2009 Jan 13;72(2):135–42. doi: 10.1212/01.wnl.0000339037.76336.cf. PMID: 19139364.19139364
179 Shumaker SA, Legault C, Rapp SR, . Estrogen plus progestin and the incidence of dementia and mild cognitive impairment in postmenopausal women: the Women’s Health Initiative Memory Study: a randomized controlled trial. JAMA. 2003 May 28;289(20):2651–62. doi: 10.1001/jama.289.20.2651. PMID: 12771112.12771112
180 Shumaker SA, Legault C, Kuller L, . Conjugated equine estrogens and incidence of probable dementia and mild cognitive impairment in postmenopausal women: Women’s Health Initiative Memory Study. JAMA. 2004 Jun 23;291(24):2947–58. doi: 10.1001/jama.291.24.2947. PMID: 15213206.15213206
181 Tierney MC, Oh P, Moineddin R, . A randomized double-blind trial of the effects of hormone therapy on delayed verbal recall in older women. Psychoneuroendocrinology. 2009 Aug;34(7):1065–74. doi: 10.1016/j.psyneuen.2009.02.009. PMID: 19297102.19297102
182 Vaughan C, Goldstein FC, Tenover JL. Exogenous testosterone alone or with finasteride does not improve measurements of cognition in healthy older men with low serum testosterone. J Androl. 2007 Nov–Dec;28(6):875–82. 10.2164/jandrol.107.002931. PMID: 17609296.17609296
183 Wroolie TE, Kenna HA, Williams KE, . Cognitive Effects of Hormone Therapy Continuation or Discontinuation in a Sample of Women at Risk for Alzheimer Disease. American Journal of Geriatric Psychiatry. 2015 01 Nov;23(11):1117–26. doi: http://dx.doi.org/10.1016/j.jagp.2015.05.009. PMID: 609354671.26209223
184 Yaffe K, Krueger K, Cummings SR, . Effect of raloxifene on prevention of dementia and cognitive impairment in older women: the Multiple Outcomes of Raloxifene Evaluation (MORE) randomized trial. Am J Psychiatry. 2005 Apr;162(4):683–90. doi: 10.1176/appi.ajp.162.4.683. PMID: 15800139.15800139
185 Yaffe K, Krueger K, Sarkar S, . Cognitive function in postmenopausal women treated with raloxifene. N Engl J Med. 2001 Apr 19;344(16):1207–13. doi: 10.1056/nejm200104193441604. PMID: 11309635.11309635
186 Yaffe K, Vittinghoff E, Ensrud KE, . Effects of ultra-low-dose transdermal estradiol on cognition and health-related quality of life. Arch Neurol. 2006 Jul;63(7):945–50. doi: 10.1001/archneur.63.7.945. PMID: 16831962.16831962
187 Finch C, Landfield P. Neuroendocrine and autonomic functions in aging mammals. Handbook of the biology of aging/editors, CE Finch, EL Schneider, with the assistance of associate editors, RC Adelman, GM Martin, EJ Masoro. 1985.
188 Hogervorst E, Williams J, Budge M, . The nature of the effect of female gonadal hormone replacement therapy on cognitive function in post-menopausal women: a meta-analysis. Neuroscience. 2000;101(3):485–512.11113299
189 Resnick SM, Maki PM, Rapp SR, . Effects of combination estrogen plus progestin hormone treatment on cognition and affect. J Clin Endocrinol Metab. 2006 May;91(5):1802–10. doi: 10.1210/jc.2005-2097. PMID: 16522699.16522699
190 Writing Group for the Women’s Health Initiative Investigators. Risks and benefits of estrogen plus progestin in healthy postmenopausal women: principal results from the Women’s Health Initiative randomized controlled trial. JAMA. 2002;288(3):321–33. PMID: 1211739712117397
191 Naeini AM, Elmadfa I, Djazayery A, . The effect of antioxidant vitamins E and C on cognitive performance of the elderly with mild cognitive impairment in Isfahan, Iran: a double-blind, randomized, placebo-controlled trial. Eur J Nutr. 2014 Aug;53(5):1255–62. doi: 10.1007/s00394-013-0628-1. PMID: 24326981.24326981
192 Brady CB, Gaziano JM, Cxypoliski RA, . Homocysteine lowering and cognition in CKD: the Veterans Affairs homocysteine study. Am J Kidney Dis. 2009 Sep;54(3):440–9. doi: 10.1053/j.ajkd.2009.05.013. PMID: 19628319.19628319
193 Carlsson CM, Papcke-Benson K, Carnes M, . Health-related quality of life and long-term therapy with pravastatin and tocopherol (vitamin E) in older adults. Drugs Aging. 2002;19(10):793–805. PMID: 12390056.12390056
194 de Jager CA, Oulhaj A, Jacoby R, . Cognitive and clinical outcomes of homocysteine-lowering B-vitamin treatment in mild cognitive impairment: a randomized controlled trial. Int J Geriatr Psychiatry. 2012 Jun;27(6):592–600. doi: 10.1002/gps.2758. PMID: 21780182.21780182
195 Douaud G, Refsum H, de Jager CA, . Preventing Alzheimer’s disease-related gray matter atrophy by B-vitamin treatment. Proc Natl Acad Sci U S A. 2013 Jun 4;110(23):9523–8. doi: 10.1073/pnas.1301816110. PMID: 23690582.23690582
196 Grodstein F, O’Brien J, Kang JH, . Long-term multivitamin supplementation and cognitive function in men: a randomized trial. Ann Intern Med. 2013 Dec 17;159(12):806–14. doi: 10.7326/0003-4819-159-12-201312170-00006. PMID: 24490265.24490265
197 Heart Protection Study Collaborative Group. MRC/BHF Heart Protection Study of antioxidant vitamin supplementation in 20,536 high-risk individuals: a randomised placebo-controlled trial. Lancet. 2002 Jul 6;360(9326):23–33. doi: 10.1016/S0140-6736(02)09328-5. PMID: 12114037.12114037
198 Kang JH, Cook N, Manson J, . A randomized trial of vitamin E supplementation and cognitive function in women. Arch Intern Med. 2006 Dec 11–25;166(22):2462–8. 10.1001/archinte.166.22.2462. PMID: 17159011.17159011
199 Kang JH, Cook NR, Manson JE, . Vitamin E, vitamin C, beta carotene, and cognitive function among women with or at risk of cardiovascular disease: The Women’s Antioxidant and Cardiovascular Study. Circulation. 2009 Jun 2;119(21):2772–80. doi: 10.1161/CIRCULATIONAHA.108.816900. PMID: 19451353.19451353
200 Kesse-Guyot E, Fezeu L, Jeandel C, . French adults’ cognitive performance after daily supplementation with antioxidant vitamins and minerals at nutritional doses: a post hoc analysis of the Supplementation in Vitamins and Mineral Antioxidants (SU.VI.MAX) trial. Am J Clin Nutr. 2011 Sep;94(3):892–9. doi: 10.3945/ajcn.110.007815. PMID: 21775560.21775560
201 McMahon JA, Green TJ, Skeaff CM, . A controlled trial of homocysteine lowering and cognitive performance. N Engl J Med. 2006 Jun 29;354(26):2764–72. doi: 10.1056/NEJMoa054025. PMID: 16807413.16807413
202 McNeill G, Avenell A, Campbell MK, . Effect of multivitamin and multimineral supplementation on cognitive function in men and women aged 65 years and over: a randomised controlled trial. Nutr J. 2007;6:10. doi: 10.1186/1475-2891-6-10. PMID: 17474991.17474991
203 Petersen RC, Thomas RG, Grundman M, . Vitamin E and donepezil for the treatment of mild cognitive impairment. N Engl J Med. 2005 Jun 9;352(23):2379–88. doi: 10.1056/NEJMoa050151. PMID: 15829527.15829527
204 Remington R, Lortie JJ, Hoffmann H, . A Nutritional Formulation for Cognitive Performance in Mild Cognitive Impairment: A Placebo-Controlled Trial with an Open-Label Extension. J Alzheimers Dis. 2015 01 Oct;48(3):591–5. 10.3233/JAD-150057. PMID: 26402075.26402075
205 Rossom RC, Espeland MA, Manson JE, . Calcium and vitamin D supplementation and cognitive impairment in the women’s health initiative. J Am Geriatr Soc. 2012 Dec;60(12):2197–205. doi: 10.1111/jgs.12032. PMID: 23176129.23176129
206 Smith A, Clark R, Nutt D, . Anti-oxidant vitamins and mental performance of the elderly. Human Psychopharmacology-Clinical and Experimental. 1999 Oct;14(7):459–71. doi: Doi 10.1002/(Sici)1099-1077(199910)14:7<459::Aid-Hup128>3.0.Co;2-0. WOS:000083485200003.
207 Smith AD, Smith SM, de Jager CA, . Homocysteine-lowering by B vitamins slows the rate of accelerated brain atrophy in mild cognitive impairment: a randomized controlled trial. PLoS One. 2010;5(9):e12244. doi: 10.1371/journal.pone.0012244. PMID: 20838622.20838622
208 van der Zwaluw NL, Dhonukshe-Rutten RA, van Wijngaarden JP, . Results of 2-year vitamin B treatment on cognitive performance: secondary data from an RCT. Neurology. 2014 Dec 2;83(23):2158–66. doi: 10.1212/WNL.0000000000001050. PMID: 25391305.25391305
209 Walker JG, Batterham PJ, Mackinnon AJ, . Oral folic acid and vitamin B-12 supplementation to prevent cognitive decline in community-dwelling older adults with depressive symptoms--the Beyond Ageing Project: a randomized controlled trial. Am J Clin Nutr. 2012 Jan;95(1):194–203. doi: 10.3945/ajcn.110.007799. PMID: 22170358.22170358
210 Wolters M, Hickstein M, Flintermann A, . Cognitive performance in relation to vitamin status in healthy elderly German women-the effect of 6-month multivitamin supplementation. Prev Med. 2005 Jul;41(1):253–9. doi: 10.1016/j.ypmed.2004.11.007. PMID: 15917019.15917019
211 Cockle S, Haller J, Kimber S, . The influence of multivitamins on cognitive function and mood in the elderly. Aging & Mental Health. 2000;4(4):339–53.
212 Durga J, van Boxtel MP, Schouten EG, . Effect of 3-year folic acid supplementation on cognitive function in older adults in the FACIT trial: a randomised, double blind, controlled trial. Lancet. 2007 Jan 20;369(9557):208–16. PMID: 17240287.17240287
213 Jack CR, Jr., Petersen RC, Grundman M, . Longitudinal MRI findings from the vitamin E and donepezil treatment study for MCI. Neurobiology of Aging. 2008 Sep;29(9):1285–95. PMID: 17452062.17452062
214 Kang JH, Cook N, Manson J, . A trial of B vitamins and cognitive function among women at high risk of cardiovascular disease. American Journal of Clinical Nutrition. 2008 Dec;88(6):1602–10. doi: http://dx.doi.org/10.3945/ajcn.2008.26404. PMID: 19064521.19064521
215 Oulhaj A, Jerneren F, Refsum H, . Omega-3 fatty acid status enhances the prevention of cognitive decline by B Vitamins in mild cognitive impairment. Journal of Alzheimer’s Disease. 2015 10 Dec;50(2):547–57. doi: http://dx.doi.org/10.3233/JAD-150777. PMID: 608047606.
216 Stott DJ, MacIntosh G, Lowe GD, . Randomized controlled trial of homocysteine-lowering vitamin treatment in elderly patients with vascular disease. American Journal of Clinical Nutrition. 2005 Dec;82(6):1320–6. PMID: 16332666.16332666
217 Yaffe K, Clemons TE, McBee WL, . Impact of antioxidants, zinc, and copper on cognition in the elderly: a randomized, controlled trial. Neurology. 2004 Nov 9;63(9):1705–7. PMID: 15534261.15534261
218 Anderson C, Teo K, Gao P, . Renin-angiotensin system blockade and cognitive function in patients at high risk of cardiovascular disease: analysis of data from the ONTARGET and TRANSCEND studies. Lancet Neurology. 2011 Jan;10(1):43–53. doi: http://dx.doi.org/10.1016/S1474-4422(10)70250-7. PMID: 20980201.20980201
219 Applegate WB, Pressel S, Wittes J, . Impact of the treatment of isolated systolic hypertension on behavioral variables. Results from the systolic hypertension in the elderly program. Archives of Internal Medicine. 1994 Oct 10;154(19):2154–60. PMID: 7944835.7944835
220 Bird AS, Blizard RA, Mann AH. Treating hypertension in the older person: an evaluation of the association of blood pressure level and its reduction with cognitive performance. Journal of Hypertension. 1990 Feb;8(2):147–52. PMID: 2162877.2162877
221 Fogari R, Mugellini A, Zoppi A, . Influence of losartan and atenolol on memory function in very elderly hypertensive patients. Journal of Human Hypertension. 2003 Nov;17(11):781–5. PMID: 14578918.14578918
222 Fogari R, Mugellini A, Zoppi A, . Effect of telmisartan/hydrochlorothiazide vs. lisinopril/hydrochlorothiazide combination on ambulatory blood pressure and cognitive function in elderly hypertensive patients. Journal of Human Hypertension. 2006 Mar;20(3):177–85. PMID: 16306998.16306998
223 Forette F, Seux ML, Staessen JA, . The prevention of dementia with antihypertensive treatment: new evidence from the Systolic Hypertension in Europe (Syst-Eur) study.[Erratum appears in Arch Intern Med. 2003 Jan 27;163(2):241.]. Archives of Internal Medicine. 2002 Oct 14;162(18):2046–52. PMID: 12374512.12374512
224 Forette F, Seux ML, Staessen JA, . Prevention of dementia in randomised double-blind placebo-controlled Systolic Hypertension in Europe (Syst-Eur) trial. Lancet. 1998 Oct 24;352(9137):1347–51. PMID: 9802273.9802273
225 Goldstein G, Materson BJ, Cushman WC, . Treatment of hypertension in the elderly: II. Cognitive and behavioral function. Results of a Department of Veterans Affairs Cooperative Study. Hypertension. 1990 Apr;15(4):361–9. PMID: 2318518.2318518
226 Gurland BJ, Teresi J, Smith WM, . Effects of treatment for isolated systolic hypertension on cognitive status and depression in the elderly. Journal of the American Geriatrics Society. 1988 Nov;36(11):1015–22. PMID: 3171039.3171039
227 Hajjar I, Hart M, Chen YL, . Antihypertensive therapy and cerebral hemodynamics in executive mild cognitive impairment: results of a pilot randomized clinical trial. Journal of the American Geriatrics Society. 2013 Feb;61(2):194–201. doi: http://dx.doi.org/10.1111/jgs.12100. PMID: 23350899.23350899
228 Lithell H, Hansson L, Skoog I, . The Study on Cognition and Prognosis in the Elderly (SCOPE): principal results of a randomized double-blind intervention trial. Journal of Hypertension. 2003 May;21(5):875–86. PMID: 12714861.12714861
229 Perez-Stable EJ, Halliday R, Gardiner PS, . The effects of propranolol on cognitive function and quality of life: a randomized trial among patients with diastolic hypertension. American Journal of Medicine. 2000 Apr 1;108(5):359–65. PMID: 10759091.10759091
230 Sato N, Saijo Y, Sasagawa Y, . Combination of antihypertensive therapy in the elderly, multicenter investigation (CAMUI) trial: results after 1 year. J Hypertens. 2013 Jun;31(6):1245–55. doi: 10.1097/HJH.0b013e32835fdf60. PMID: 23492647.23492647
231 Saxby BK, Harrington F, Wesnes KA, . Candesartan and cognitive decline in older patients with hypertension: a substudy of the SCOPE trial. Neurology. 2008 May 6;70(19 Pt 2):1858–66. doi: http://dx.doi.org/10.1212/01.wnl.0000311447.85948.78. PMID: 18458219.18458219
232 Skoog I, Lithell H, Hansson L, . Effect of baseline cognitive function and antihypertensive treatment on cognitive and cardiovascular outcomes: Study on COgnition and Prognosis in the Elderly (SCOPE). American Journal of Hypertension. 2005 Aug;18(8):1052–9. PMID: 16109319.16109319
233 Starr JM, Whalley LJ. Differential cognitive outcomes in the Hypertensive Old People in Edinburgh study. Journal of the Neurological Sciences. 2005 Mar 15;229–230:103–7. PMID: 15760627.15760627
234 Starr JM, Whalley LJ, Deary IJ. The effects of antihypertensive treatment on cognitive function: results from the HOPE study. Journal of the American Geriatrics Society. 1996 Apr;44(4):411–5. PMID: 8636587.8636587
235 Tedesco MA, Ratti G, Mennella S, . Comparison of losartan and hydrochlorothiazide on cognitive function and quality of life in hypertensive patients. American Journal of Hypertension. 1999 Nov;12(11 Pt 1):1130–4. PMID: 10604491.10604491
236 Williamson JD, Launer LJ, Bryan RN, . Cognitive function and brain structure in persons with type 2 diabetes mellitus after intensive lowering of blood pressure and lipid levels: a randomized clinical trial. JAMA Intern Med. 2014 Mar;174(3):324–33. doi: 10.1001/jamainternmed.2013.13656. PMID: 24493100.24493100
237 Yodfat Y, Bar-On D, Amir M, . Quality of life in normotensives compared to hypertensive men treated with isradipine or methyldopa as monotherapy or in combination with captopril: the LOMIR-MCT-IL study. Journal of Human Hypertension. 1996 Feb;10(2):117–22. PMID: 8867566.8867566
238 SHEP Cooperative Research Group. Prevention of stroke by antihypertensive drug treatment in older persons with isolated systolic hypertension. Final results of the Systolic Hypertension in the Elderly Program (SHEP). SHEP Cooperative Research Group. JAMA. 1991 Jun 26;265(24):3255–64. PMID: 2046107.2046107
239 Patel A, Group AC, MacMahon S, . Effects of a fixed combination of perindopril and indapamide on macrovascular and microvascular outcomes in patients with type 2 diabetes mellitus (the ADVANCE trial): a randomised controlled trial. Lancet. 2007 Sep 8;370(9590):829–40. PMID: 17765963.17765963
240 Peters R, Beckett N, Forette F, . Incident dementia and blood pressure lowering in the Hypertension in the Very Elderly Trial cognitive function assessment (HYVET-COG): a double-blind, placebo controlled trial. Lancet Neurology. 2008 Aug;7(8):683–9. doi: http://dx.doi.org/10.1016/S1474-4422(08)70143-1 (http://dx.doi.org/10.1016/S1474-4422(08). PMID: 18614402.18614402
241 Prince MJ, Bird AS, Blizard RA, . Is the cognitive function of older patients affected by antihypertensive treatment? Results from 54 months of the Medical Research Council’s trial of hypertension in older adults. BMJ. 1996 Mar 30;312(7034):801–5. PMID: 8608285.8608285
242 Barnes D, Yaffe K. The projected effect of risk factor reduction on Alzheimer’s disease prevalence. Lancet Neurology. 2011 Sept 2011;10(9):819–28. doi: 10.1016/S1474-4422(11)70072-2. PMID: 21775213.21775213
243 Heart Protection Study Collaborative Group. MRC/BHF Heart Protection Study of cholesterol lowering with simvastatin in 20,536 high-risk individuals: a randomised placebo-controlled trial. Lancet. 2002 Jul 6;360(9326):7–22. doi: 10.1016/S0140-6736(02)09327-3. PMID: 12114036.12114036
244 Muldoon MF, Barger SD, Ryan CM, . Effects of lovastatin on cognitive function and psychological well-being. Am J Med. 2000 May;108(7):538–46. PMID: 10806282.10806282
245 Muldoon MF, Ryan CM, Sereika SM, . Randomized trial of the effects of simvastatin on cognitive functioning in hypercholesterolemic adults. Am J Med. 2004 Dec 1;117(11):823–9. doi: 10.1016/j.amjmed.2004.07.041. PMID: 15589485.15589485
246 Parale GP, Baheti NN, Kulkarni PM, . Effects of atorvastatin on higher functions. Eur J Clin Pharmacol. 2006 Apr;62(4):259–65. doi: 10.1007/s00228-005-0073-z. PMID: 16489473.16489473
247 Santanello NC, Barber BL, Applegate WB, . Effect of pharmacologic lipid lowering on health-related quality of life in older persons: results from the Cholesterol Reduction in Seniors Program (CRISP) Pilot Study. J Am Geriatr Soc. 1997 Jan;45(1):8–14. PMID: 8994481.8994481
248 Tendolkar I, Enajat M, Zwiers MP, . One-year cholesterol lowering treatment reduces medial temporal lobe atrophy and memory decline in stroke-free elderly with atrial fibrillation: evidence from a parallel group randomized trial. Int J Geriatr Psychiatry. 2012 Jan;27(1):49–58. doi: 10.1002/gps.2688. PMID: 21308791.21308791
249 Trompet S, van Vliet P, de Craen AJ, . Pravastatin and cognitive function in the elderly. Results of the PROSPER study. J Neurol. 2010 Jan;257(1):85–90. doi: 10.1007/s00415-009-5271-7. PMID: 19653027.19653027
250 Shepherd J, Blauw GJ, Murphy MB, . Pravastatin in elderly individuals at risk of vascular disease (PROSPER): a randomised controlled trial. Lancet. 2002 Nov 23;360(9346):1623–30. PMID: 12457784.12457784
251 Barnard N, Bunner A, Agarwal U. Saturated and trans fats and dementia: a systematic review. Neurobiol Aging 2014;35:Suppl 2:S65–73. 10.1016/j.neurobiolaging.2014.02.030. PMID: 2491658224916582
252 FDA. FDA Drug Safety Communication: Important safety label changes to cholesterol-lowering statin drugs. 2012. http://www.fda.gov/drugs/drugsafety/ucm293101.htm.
253 Ott B, Daiello L, Dahabreh I, . Do statins impair cognition? A systematic review and meta-analysis of randomized controlled trials. J Gen Intern Med. 2015 Mar 2015;30(3):348–58. doi: 10.1007/s11606-014-3115-3. PMID: 25575908.25575908
254 Power M, Weuve J, Sharrett A, . Statins, cognition, and dementia—systematic review and methodological commentary. Nat Rev Neurol. 2015 Apr 2015;11(4):220–9. doi: 10.1038/nrneurol.2015.35. PMID: 25799928.25799928
255 Adapt Research Group. Results of a follow-up study to the randomized Alzheimer’s Disease Anti-inflammatory Prevention Trial (ADAPT). Alzheimer’s & Dementia. 2013 Nov;9(6):714–23. doi: http://dx.doi.org/10.1016/j.jalz.2012.11.012. PMID: 23562431.23562431
256 Adapt Research Group, Lyketsos CG, Breitner JC, . Naproxen and celecoxib do not prevent AD in early results from a randomized controlled trial. Neurology. 2007 May 22;68(21):1800–8. PMID: 17460158.17460158
257 Adapt Research Group, Martin BK, Szekely C, . Cognitive function over time in the Alzheimer’s Disease Anti-inflammatory Prevention Trial (ADAPT): results of a randomized, controlled trial of naproxen and celecoxib. Archives of Neurology. 2008 Jul;65(7):896–905. doi: http://dx.doi.org/10.1001/archneur.2008.65.7.nct70006. PMID: 18474729.18474729
258 Breitner JC, Baker LD, Montine TJ, . Extended results of the Alzheimer’s disease anti-inflammatory prevention trial. Alzheimer’s & Dementia. 2011 Jul;7(4):402–11. doi: http://dx.doi.org/10.1016/j.jalz.2010.12.014. PMID: 21784351.21784351
259 Kang JH, Cook N, Manson J, . Low dose aspirin and cognitive function in the women’s health study cognitive cohort. BMJ. 2007 May 12;334(7601):987. PMID: 17468120.17468120
260 Small GW, Siddarth P, Silverman DH, . Cognitive and cerebral metabolic effects of celecoxib versus placebo in people with age-related memory loss: randomized controlled study. American Journal of Geriatric Psychiatry. 2008 Dec;16(12):999–1009. doi: http://dx.doi.org/10.1097/JGP.0b013e31818cd3a4. PMID: 19038899.19038899
261 Thal LJ, Ferris SH, Kirby L, . A randomized, double-blind, study of rofecoxib in patients with mild cognitive impairment. Neuropsychopharmacology. 2005 Jun;30(6):1204–15. PMID: 15742005.15742005
262 McGeer PL, Schulzer M, McGeer EG Arthritis and anti-inflammatory agents as possible protective factors for Alzheimer’s disease: a review of 17 epidemiologic studies. Neurology. 1996 Aug;47(2):425–32. PMID: 8757015.8757015
263 Devi G, Massimi S, Schultz S, . A double-blind, placebo-controlled trial of donepezil for the treatment of menopause-related cognitive loss. Gend Med. 2007 Dec;4(4):352–8. PMID: 18215726.18215726
264 Doody RS, Ferris SH, Salloway S, . Donepezil treatment of patients with MCI: a 48-week randomized, placebo-controlled trial. Neurology. 2009 May 5;72(18):1555–61. doi: 10.1212/01.wnl.0000344650.95823.03. PMID: 19176895.19176895
265 Feldman HH, Ferris S, Winblad B, . Effect of rivastigmine on delay to diagnosis of Alzheimer’s disease from mild cognitive impairment: the InDDEx study. Lancet Neurol. 2007 Jun;6(6):501–12. doi: 10.1016/S1474-4422(07)70109-6. PMID: 17509485.17509485
266 Gavrilova SI, Kolykhalov IV, Fedorova YB, . Potential of Preventive Treatment of Alzheimer’s Disease: Results of a Three-Year Prospective Open Comparative Trial of the Efficacy and Safety of Courses of Treatment with Cerebrolysin and Cavinton in Elderly Patients with Mild Cognitive Impairment Syndrome. Neuroscience and Behavioral Physiology. 2011 May;41(4):391–8. doi: 10.1007/s11055-011-9427-4. PMID: 2011362050.
267 Peters O, Lorenz D, Fesche A, . A combination of galantamine and memantine modifies cognitive function in subjects with amnestic MCI. J Nutr Health Aging. 2012;16(6):544–8. PMID: 22659994.22659994
268 Petrella JR, Prince SE, Krishnan S, . Effects of donepezil on cortical activation in mild cognitive impairment: a pilot double-blind placebo-controlled trial using functional MR imaging. AJNR Am J Neuroradiol. 2009 Feb;30(2):411–6. doi: 10.3174/ajnr.A1359. PMID: 19001543.19001543
269 Reynolds CF, 3rd, Butters MA, Lopez O, . Maintenance treatment of depression in old age: a randomized, double-blind, placebo-controlled evaluation of the efficacy and safety of donepezil combined with antidepressant pharmacotherapy. Arch Gen Psychiatry. 2011 Jan;68(1):51–60. doi: 10.1001/archgenpsychiatry.2010.184. PMID: 21199965.21199965
270 Salloway S, Ferris S, Kluger A, . Efficacy of donepezil in mild cognitive impairment: a randomized placebo-controlled trial. Neurology. 2004 Aug 24;63(4):651–7. PMID: 15326237.15326237
271 Schuff N, Suhy J, Goldman R, . An MRI substudy of a donepezil clinical trial in mild cognitive impairment. Neurobiol Aging. 2011 Dec;32(12):2318 e31–41. doi: 10.1016/j.neurobiolaging.2010.04.005. PMID: 20541841.20541841
272 Winblad B, Gauthier S, Scinto L, . Safety and efficacy of galantamine in subjects with mild cognitive impairment. Neurology. 2008 May 27;70(22):2024–35. doi: 10.1212/01.wnl.0000303815.69777.26. PMID: 18322263.18322263
273 Prins ND, van der Flier WA, Knol DL, . The effect of galantamine on brain atrophy rate in subjects with mild cognitive impairment is modified by apolipoprotein E genotype: post-hoc analysis of data from a randomized controlled trial. Alzheimers Res Ther 2014 21 Jul;6(4):47. 10.1186/alzrt275. PMID: 25478019.25478019
274 Diniz BS, Pinto JA, Jr., Gonzaga ML, . To treat or not to treat? A meta-analysis of the use of cholinesterase inhibitors in mild cognitive impairment for delaying progression to Alzheimer’s disease. Eur Arch Psychiatry Clin Neurosci. 2009 June 2009;259(4):248–56. doi: 10.1007/s00406-008-0864-1. PMID: 19224111.19224111
275 Birks J, Flicker L Donepezil for mild cognitive impairment. Cochrane Database of Systematic Reviews. 2006 Jul 2006;19(3) PMID: 1685611416856114
276 Russ T, Morling J Cholinesterase inhibitors for mild cognitive impairment. Cochrane Database of Systematic Reviews. 2012 Sept 2012;12(9)doi: 10.1002/14651858.CD009132.pub2. PMID: 2297213322972133
277 Luchsinger JA, Perez T, Chang H, . Metformin in Amnestic Mild Cognitive Impairment: Results of a Pilot Randomized Placebo Controlled Clinical Trial. J Alzheimer’s Dis. 2016;51(2):501–14. doi: 10.3233/JAD-150493. PMID: 2689073626890736
278 Cheatham RA, Roberts SB, Das SK, . Long-term effects of provided low and high glycemic load low energy diets on mood and cognition. Physiol Behav. 2009 Sep 7;98(3):374–9. doi: 10.1016/j.physbeh.2009.06.015. PMID: 19576915.19576915
279 Koekkoek PS, Ruis C, van den Donk M, . Intensive multifactorial treatment and cognitive functioning in screen-detected type 2 diabetes--the ADDITION-Netherlands study: a cluster-randomized trial. J Neurol Sci. 2012 Mar 15;314(1–2):71–7. doi: 10.1016/j.jns.2011.10.028. PMID: 22093142.22093142
280 Launer LJ, Miller ME, Williamson JD, . Effects of intensive glucose lowering on brain structure and function in people with type 2 diabetes (ACCORD MIND): a randomised open-label substudy. Lancet Neurol. 2011 Nov;10(11):969–77. doi: 10.1016/S1474-4422(11)70188-0. PMID: 21958949.21958949
281 Luchsinger JA, Palmas W, Teresi JA, . Improved diabetes control in the elderly delays global cognitive decline. J Nutr Health Aging. 2011 Jun;15(6):445–9. PMID: 21623465.21623465
282 Seaquist ER, Miller ME, Fonseca V, . Effect of thiazolidinediones and insulin on cognitive outcomes in ACCORD-MIND. J Diabetes Complications. 2013 Sep–Oct;27(5):485–91. 10.1016/j.jdiacomp.2013.03.005. PMID: 23680059.23680059
283 Cheng G, Huang C, Deng H, . Diabetes as a risk factor for dementia and mild cognitive impairment: a meta-analysis of longitudinal studies. Intern Med. 2012 May 2012;42(5):484–91. doi: 10.1111/j.1445-5994.2012.02758.x. PMID: 22372522.22372522
284 Williamson JD, Miller ME, Bryan RN, . The Action to Control Cardiovascular Risk in Diabetes Memory in Diabetes Study (ACCORD-MIND): rationale, design, and methods. Am J Cardiol. 2007 Jun 18;99(12A):112i–22i. doi: 10.1016/j.amjcard.2007.03.029. PMID: 17599421.17599421
285 Origin Trial Investigators, Gerstein HC, Bosch J, . Basal insulin and cardiovascular and other outcomes in dysglycemia. N Engl J Med. 2012 Jul 26;367(4):319–28. doi: 10.1056/NEJMoa1203858. PMID: 22686416.22686416
286 Lucassen EA, Piaggi P, Dsurney J, . Sleep extension improves neurocognitive functions in chronically sleep-deprived obese individuals. PLoS One. 2014;9(1):e84832. doi: 10.1371/journal.pone.0084832. PMID: 24482677.24482677
287 Sun J, Kang J, Wang P, . Self-relaxation training can improve sleep quality and cognitive functions in the older: a one-year randomised controlled trial. J Clin Nurs. 2013 May;22(9–10):1270–80. doi: 10.1111/jocn.12096. PMID: 23574290.23574290
288 Bugos JA, Perlstein WM, McCrae CS, . Individualized piano instruction enhances executive functioning and working memory in older adults. Aging Ment Health. 2007 Jul;11(4):464–71. doi: 10.1080/13607860601086504. PMID: 17612811.17612811
289 Forlenza OV, Diniz BS, Radanovic M, . Disease-modifying properties of long-term lithium treatment for amnestic mild cognitive impairment: randomised controlled trial. Br J Psychiatry. 2011 May;198(5):351–6. doi: 10.1192/bjp.bp.110.080044. PMID: 21525519.21525519
290 Newhouse P, Kellar K, Aisen P, . Nicotine treatment of mild cognitive impairment: a 6-month double-blind pilot clinical trial. Neurology. 2012 Jan 10;78(2):91–101. doi: 10.1212/WNL.0b013e31823efcbb. PMID: 22232050.22232050
291 Snowball A, Tachtsidis I, Popescu T, . Long-term enhancement of brain function and cognition using cognitive training and brain stimulation. Curr Biol. 2013 Jun 3;23(11):987–92. doi: 10.1016/j.cub.2013.04.045. PMID: 23684971.23684971
292 Sonnen J, Montine K, Quinn J, . Biomarkers for cognitive impairment and dementia in elderly people. Lancet Neurology. 2008 Aug 2008;7(8):704–14. doi: 10.1016/S1474-4422(08)70162-5. PMID: 18635019.18635019
293 Espeland MA, Rapp SR, Bray GA, . Long-term impact of behavioral weight loss intervention on cognitive function. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2014;69(9):1101–8. PMID: 24619151.24619151
294 Eklund A, Nichols TE, Knutsson H Cluster failure: Why fMRI inferences for spatial extent have inflated false-positive rates. Proceedings of the National Academy of Sciences of the United States of America. 2016 2016 July 12;113(28):7900–5. doi: 10.1073/pnas.1602413113. PMID: 27357684.27357684