# Key Informants and Technical Expert Panel

The role of the Key Informants was filled by the National Academies of Sciences, Engineering, and Medicine Committee on Preventing Dementia and Cognitive Impairment, which will use the report to help develop its own recommendations report on the state of knowledge on the efficacy, comparative effectiveness, and harms of interventions to prevent or delay the onset of age-related cognitive decline, mild cognitive impairment, or clinical Alzheimer’s-type dementia for the National Academies and the National Institute on Aging. (An overview of the National Academies’ conflict-of-interest policies can be found at http://nationalacademies.org/studyprocess/index.html; detailed information is available at http://www8.nationalacademies.org/cp/information.aspx?key=Conflict_of_Interest.) Because the National Academies Committee would not see the draft Key Questions, PICOTS (populations, interventions, comparators, outcomes, timing, and settings), and analytic framework until the Key Questions were posted for public comment, a panel of content experts from Federal agencies acted as proxy Key Informants prior to posting. The proxy Key Informants disclosed any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. The role of the Technical Expert Panel (TEP) was filled by the National Academies Committee.

The list of proxy Key Informants who provided input to this report follows:

- Susan Cooley, Ph.D.
  Chief, Geriatric Research & Evaluation
  U.S. Department of Veterans Affairs
  Washington, DC
- Rod Corriveau, Ph.D.
  Program Director, Extramural Research Program
  National Institute of Neurological Disorders and Stroke
  Washington, DC
- Jonathan King, Ph.D.
  Program Director, Division of Behavioral and Social Research
  National Institute on Aging
  Washington, DC
- Lisa McGuire, Ph.D.
  Lead, Alzheimer’s Disease and Healthy Aging Program
  Centers for Disease Control & Prevention
  Atlanta, GA
- Claudia Moy, Ph.D.
  Program Director, Office of Clinical Research
  National Institute of Neurological Disorders and Stroke
  Washington, DC
- Laurie Ryan, Ph.D.
  Chief, Dementias of Aging
  National Institute on Aging
  Washington, DC
- Jane Tilly, Dr.P.H., M.P.A.
  Brain Health and Dementia Programs Team Lead
  Administration for Community Living
  Washington, DC
- Molly Wagster, Ph.D.
  Chief, Behavioral and Systems Neuroscience Branch
  National Institute on Aging
  Washington, DC