# Acknowledgments

We wish to thank Stephanie Trudeau and McKay Winzenried, who helped as research assistants; Cheryl Cole-Hill, Marianna Valadez, and Nancy Russell for their assistance in producing this report; and Melissa McPheeters, Melinda Kelley, Kim Wittenberg, and David Niebuhr for their helpful comments and edits during the writing process.