# 7 Suggestions for Future Research

The ability to draw meaningful conclusions regarding interventions that can delay or slow age-related cognitive decline and prevent onset of mild cognitive impairment (MCI) or clinical Alzheimer’s-type dementia (CATD) is hampered by limitations in existing research. The bulk of the studies examined raise more questions than answers. Low-strength evidence in some areas may provide guidance for prioritizing the types of interventions that deserve further study. However, common problems with study design/methodology and measurement need to be rectified in future research if effective methods of preventing cognitive deterioration in older age are to be identified.

## Prioritizing Future Research

Effective use of scarce research dollars will require substantial investments in a limited number of well-designed trials of sufficient power and duration. Interventions selected to receive funding will need to be chosen carefully. The full effects of hypertension control should include attention to stroke. Priority should be given to interventions that already show some promise, most notably cognitive training and physical activity. However, the decision to exclude specific stroke-related dementia may underestimate the effect of antihypertension treatment. Although it cannot be said with complete certainty that other types of interventions have no effect, work examining hormone replacement therapy, nonsteroidal anti-inflammatory drugs (NSAIDS), statins, nutraceuticals, and others has shown little promise. Moderate-strength evidence showing no benefit for vitamin E for cognitive performance support assigning low priority to this area.

## Study Design/Methodology

Future trials should be designed intentionally to study methods of slowing and preventing age-related cognitive decline, MCI, and CATD incidence. Many studies originally designed for other purposes have added cognitive measures post-hoc. These “add-on” trials have frequently used less sophisticated measures, have not adequately evaluated baseline characteristics, and have not randomly assign participants, all of which confound data and limit conclusions.

Another common limitation is that most trials have been too short to observe clinically meaningful change in cognitive function. Many were designed with an intervention period of one year or less with limited or no follow-up, making it impossible to draw conclusions about longer-term outcomes in most cases. Trials that address dementia incidence must be even larger and longer. Designing trials of appropriate duration requires careful consideration of several key factors, including cohort characteristics (e.g., subject age, presence or absence of known risk factors of cognitive decline, cognitively normal versus MCI) and whether outcomes are intended to detect a delay in cognitive decline or a reduction in dementia incidence. Focusing on longitudinal investigations with followup periods of 10 years or more would greatly benefit the field and provide more insight about prevention. This will also require designing studies to actively minimize, or at least appropriately deal with, attrition. One way to accomplish this is by prioritizing enrollment of older cohorts although it is important to note that the most ideal age for intervention remains unknown and may vary by type of intervention. The danger of this strategy, however, lies in the possibility that treatment effects are stronger for persons in midlife than in late life. Epidemiological studies in hypertension point in this direction.

In addition to dedicated trials, larger sample sizes and longer intervention and followup periods, studies that assess dose-response relationships and underlying mechanisms of action are needed. Establishing the dose-response relationship can be done in two ways. Multiple arms of varying dosage could be used initially; alternatively, once an effect has been demonstrated, studies that assess dose-response relationships and underlying mechanisms of action could be implemented. Knowing that a specific intervention, such as cognitive training or a particular form of physical activity, could meaningfully impact dementia incidence is only helpful to the extent that various intensities of the intervention have been studied and reported. Equally important is more clearly elucidating the specific mechanisms associated with positive effects. For example, the underlying logic linking physical activity to improved cognitive performance has historically been physiological effects on blood or oxygen supply or stimulation of neurochemicals. However, the fact that remarkably different forms of physical activity, such as resistance training and aerobic exercise, show possible effects on cognition suggests that the mechanism of action may need to be reconsidered. Perhaps the effect lies in socialization, which could help explain positive effects associated with group-based cognitive training, but not similar training done alone.

Finally, the vast majority of studies testing the effectiveness of interventions to delay or slow age-related cognitive decline or prevent onset of MCI or CATD have focused narrowly on a single intervention. Given that the causes of dementia are complex and multifactorial, studies should address interventions that modify multiple risk factors. Several such trials, focusing on multiple risk factors simultaneously (multidomain interventions) have been initiated.^14^ Three of these trials (FINGER, MAPT, PreDIVA) enrolled older adults and implemented multidomain interventions with components addressing nutrition, physical activity, cognitive training, social activity, and/or vascular risk factor management. Of the two studies with published results, while the more clinical multidomain PreDIVA trial did not find benefit,^141^ results from the FINGER trial, which used a more lifestyle-based approach, were promising.^142^ More studies assessing a combination of interventions would benefit the field. The key issue in designing such studies is choosing the best “package” of interventions. Current wisdom suggests that randomized controlled trials (RCTs) should use the most powerful combinations and leave the decisions about less potent versions to subsequent studies. The first critical question is whether a combination of strong interventions can achieve the goal.

## Measurement

Consistent shortcomings across existing studies reveal many opportunities to improve the measurement techniques of future trials. Future research should employ a more consistent set of validated tests to assess cognitive performance. To date, cognitive outcomes have been measured using a wide array of neuropsychological tests. This practice is problematic because the ability to detect change in cognitive performance over time is greatly influenced by the sensitivity, specificity, and reliability of the test. Although there are no perfect tests, the psychometric properties of neuropsychological measures vary considerably. For this reason, some are probably preferred over others. In addition, the sheer volume of cognitive measures used in the literature complicates comparisons across trials, particularly when an attempt is made to cluster or group tests into domains as most do not fit neatly into one category. Moreover, it is not uncommon for studies to use many tests over several time periods without any correction for multiple comparisons. Practice effects are also a concern when participants are evaluated at timeframes designed to complement the duration of the study but not at intervals acceptable for repeated applications of the tests. Research in the field could be enhanced greatly through development of consensus guidelines that encourage investigators to use a common core standardized battery or batteries of tests in these trials. Such a model has precedence in the pharmaceutical industry, and in Alzheimer’s disease clinical trial research specifically, which unified methodology many years ago using the Alzheimer’s Disease Assessment Scale-Cognitive Subscale (ADAS-Cog) and by defining appropriate test/re-test timeframes. Although no one measure is adequate for all applications, movement towards the use of batteries with good psychometric qualities and already in common use in aging populations (such as those included in the National Alzheimer’s Coordinating Center data set https://www.alz.washington.edu/WEB/forms_uds.html or drawn from the National Institutes of Health Toolbox http://www.healthmeasures.net/explore-measurement-systems/nih-toolbox) could potentially help to narrow the field.

The baseline status of participants needs to be better measured and documented. Baseline cognitive status is variously described and often not tested. While some researchers measured baseline cognitive function as part of the trial design, the degree of measurement varied widely (e.g., brief cognitive screening versus more elaborate neuropsychological test performance). Complicating matters, some trials describe participants with terms like “normal” or “presumed healthy” while in other cases participants are described as having cognitive complaints but no diagnosis. Self-reported cognitive status is not an acceptable proxy for objective measurement. Studies examining the impact of physical activity on cognitive performance report enrolling “sedentary” adults yet fail to define exactly what this means or how this classification was determined. Standardization or common understanding of such terms is lacking. The use of appropriate attention controls can help identify the effects specific to the intervention versus those that arise from other specific factors (e.g., socialization or general therapeutic relationships).

Finally, future research trials that include incident CATD as a study outcome should evaluate participants using formal diagnostic guidelines for Alzheimer’s disease such as those from the National Institute on Aging (NIA) and the Alzheimer’s Association.^6^ Including both measures of cognitive performance and CATD incidence as study outcomes would allow researchers to better understand how these two constructs are related. Important questions include: 1) what patterns of cognitive change predict dementia? 2) do some domains predict better than others and therefore become more important targets of intervention? 3) does the difference lie in the number of cognitive domains affected? 4) is the rate of change important? and 5) in what specific populations are particular interventions most effective—in healthy adults or those with mild cognitive impairment or other risk factors? These questions, in turn, reflect the diagnostic criteria used to identify dementia. For trials that cannot include incident CATD as an outcome for whatever reason, more work is needed to define what degree of change in neuropsychological test performance is considered clinically meaningful. This question still lacks consensus, and a range of values may be needed to establish what is considered clinically meaningful and to whom. Moreover, meaningful change may vary depending upon differing baseline level of function. Consistently including objective and performance-based measures of everyday function (IADLs) in future trials may help address these questions.