# 6 Conclusion

Table 6.1 provides a summary of the key messages from the results chapters detailing intervention results. Of the 13 classes of interventions examined, we found no high-strength evidence for any intervention to delay or prevent age-related cognitive decline, mild cognitive impairment (MCI), and/or clinical Alzheimer’s-type dementia (CATD). A few specific interventions reached moderate-strength evidence for no benefit in cognitive performance: vitamin E in women; and angiotensin converting enzyme inhibitors (AC)E and thiazide versus placebo and antiotensin receptor blockers (ARBs) versus placebo on specifically brief cognitive screening tests. We found low-strength evidence that the selective estrogen receptor modulator (SERM) raloxifene reduced risk of probable MCI, however, there was also low-strength evidence that estrogen replacement with or without progestin therapy increased the risk of MCI and CATD.

Table 6.1 Summary of results chapters key messages

Intervention | Key Message
Cognitive Training | - Most studies addressed intermediate outcomes of cognitive training in terms of cognitive performance and a few measures of brain activity.; - The Advanced Cognitive Training for Independent and Vital Elderly (ACTIVE) trial provided the strongest and most comprehensive design to assess the effect of cognitive training on cognitive performance for older adults with normal cognition. Its results provide moderate-strength evidence at 2 years (but low-strength at 5 and 10 years) that cognitive training can improve cognitive function in the domain trained, but transfer to other domains was rare. There is some suggestion that processing speed training is associated with improved IADL performance, but longer term studies were rated as low strength of evidence.; - Other than the ACTIVE trial, the few studies that examined CATD incidence or cognitive performance showed mixed results.
Physical Activity Interventions | - Studies of physical activity interventions examined a wide variety of activities potentially targeting different pathways to affect cognition.; - Evidence is insufficient to conclude whether physical activity interventions prevent MCI or CATD incidence.; - Low-strength evidence shows that multicomponent physical activity interventions offer no clear benefit in cognitive performance over attention control in adults with normal cognition.; - Evidence was insufficient to conclude whether other types of physical activity interventions had benefits for cognitive outcomes in adults with normal cognition.; - While the majority of results showed no significant difference, the pattern of results across very different types of physical activity interventions provides an indication of effectiveness of physical activity.
Nutraceutical Interventions | - Low-strength evidence suggests omega-3 fatty acids and ginkgo biloba did not reduce CATD incidence or improve cognitive performance in adults with normal cognition.; - Evidence is insufficient to conclude whether resveratrol or plant sterol/stanol esters reduced CATD incidence or improved cognitive performance in adults with normal cognition.; - Few studies examined the effects of nutraceuticals on adults with MCI.
Diet Interventions | - Evidence is insufficient to conclude whether protein supplementation or energy-deficit diets have an effect on cognitive performance or incidence of MCI or CATD.
Multimodal Interventions | - Evidence is insufficient to conclude whether most multimodal interventions offer benefits for cognitive performance or incidence of MCI or CATD, largely because few studies have examined interventions with similar components.; - Low-strength evidence shows that a multimodal intervention composed of diet, physical activity, and cognitive training provides benefits in executive function/attention/processing speed.; - Low-strength evidence shows that a multimodal intervention composed of lifestyle advice and drug treatment is not effective in reducing incidence of CATD or benefiting brief cognitive test performance or memory.
Hormone Therapy Interventions | - Hormone therapy shows mixed results of harms and benefits.; - Low-strength evidence suggests that estrogen therapy may slightly increase the risk of probable MCI and CATD when the two diagnostic categories are examined together.; - Low-strength evidence suggests that estrogen plus progestin therapy may slightly increase the risk of probable CATD.; - Low-strength evidence suggests that raloxifene may decrease the risk of MCI but not the risk of CATD or of a combined outcome of MCI or CATD compared to placebo.; - In addition to these outcomes, hormone therapy has been associated with serious adverse events, including increased risk of certain cancers and cardiovascular disease
Vitamin Interventions | - Moderate-strength evidence shows no benefit in cognitive performance for vitamin E in women.; - B vitamins show mixed findings.; - Low-strength evidence for folic acid (0.4 mg) plus vitamin B_12_ (0.1–0.5 mg) shows benefit in brief cognitive test performance and memory.; - Moderate-strength evidence shows no benefit for folic acid (0.4 mg) plus B_12_ (0.1–0.5 mg) versus placebo for executive/attention/processing speed.; - Low-strength evidence for vitamin B_12_ (0.02=0.5 mg), B_6_ (3–10 mg), and folate (0.56–1 mg) shows no benefit for executive/attention/processing speed.; - Low-strength evidence shows no benefit in cognitive performance for multivitamins, vitamin C (in women), vitamin D with calcium (in women), or beta carotene (in women).; - Low-strength evidence shows no benefit in incident MCI or CATD for multivitamins or vitamin D with calcium.; - In adults with MCI, low-strength evidence shows no benefit for vitamin E in incident CATD.
Antihypertensive Treatment | - Generally, low-strength evidence shows that 3 to 4.7 years of antihypertensive treatment regimens versus placebo appear to have no benefit on cognitive test performance in adults with normal cognition.; - Moderate-strength evidence shows that angiotensin converting enzyme (ACE) plus thiazide versus placebo and angiotensin receptor blockers (ARBs) versus placebo have no benefit on brief cognitive screening tests.; - Low-strength evidence shows that intensive versus standard antihypertensive control shows no benefit on cognitive test performance.; - Low-strength evidence shows no benefit on cognitive test performance of any fixed antihypertensive treatment regimen versus another among those directly compared.; - Effects of stepped multiple agent antihypertensive medication regimens to reduce risk of dementia are inconsistent; one trial showed a positive effect but three other trials found no effect of antihypertensive treatment on CATD incidence.; - The only two trials that reported subgroup data found no differential effect of treatment group on cognition by participant age or other baseline characteristics.
Lipid Lowering Treatment | - Evidence was insufficient to assess the effect of 5 years of statin treatment on the risk of incident CATD or for preventing MCI.; - Low-strength evidence shows a small, 6-month improvement in executive/attention/processing speed with placebo treatment that was not found with statin treatment, presumed to be due to practice effects and of uncertain clinical significance.; - Low-strength evidence shows no benefit on brief cognitive test performance, executive/attention/processing speed, or memory for statin plus fenofibrate versus statin plus placebo in adults with normal cognition.; - Evidence was insufficient to assess whether effects of statins on any cognitive outcomes differ by patient age, baseline lipid level, or other characteristics.
Nonsteroidal Anti-inflammatory Drugs (NSAIDs) | - No evidence was available for the effect of low-dose aspirin on MCI or CATD incidence.; - Low-strength evidence shows no benefit for low-dose aspirin on brief cognitive screening tests, multidomain neuropsychological performance, or memory, even with 10 years of use.; - Low-strength evidence shows no benefit for nonsteroidal anti-inflammatory drugs (NSAIDs), including both selective and nonselective cyclooxygenase-2 (COX-2) inhibitors, to reduce CATD incidence, or to benefit multidomain neuropsychological performance or memory, with 8 years of followup after 1 to 3 years of use.
Antidementia Treatments | - Low-strength evidence shows acetylcholinesterase inhibitor (AChEI) antidementia drugs did not reduce the incidence of CATD in persons with MCI over 3 years; evidence is insufficient for persons with normal cognition.; - Low-strength evidence shows AChEIs for 3 years provide no significant effect on cognitive performance in adults with MCI.
Diabetes Medication Treatment | - No studies reported on the effect of diabetes treatment on the risk of incident clinical diagnoses of MCI or CATD.; - In middle-aged older adults with diabetes and presumed normal cognition, low-strength evidence shows intensive versus standard glycemic control had no significant effect on cognitive performance.
Other Interventions | - Evidence was insufficient for lithium, a nicotine patch, individual piano instruction, multitask rhythmic exercise to music, sleep interventions, and social engagement.; - We found no relevant studies for depression treatments, smoking cessation, or community-level interventions.
Agreement of Biomarkers and Measures of Cognitive Performance | - Only a few (9) low or medium risk of bias studies for cognitive performance also used biomarker measures; most of those used some form of brain scan.; - The overall rate of agreement between biomarker measures and cognitive testing was 57 percent, but 90 percent of that agreement resulted from both approaches showing no effect. When the biomarker measure showed a significant result, there was agreement in 25 percent of cognitive tests conducted.

CATD=clinical Alzheimer’s-type dementia; MCI=mild cognitive impairment

A few intervention types show more potential than others at benefiting cognitive performance. We found moderate-strength evidence that cognitive training can improve cognitive function in the domain trained up to 2 years (low strength of evidence at 5 and 10 years), but generalization/transfer to other domains was rare. Although there was some evidence for improvement in instrumental activities of daily living (IADLs), these studies had design problems and short-term studies may not predict long-term outcomes. Moreover, IADLs may be a benefit per se, but are not directly linked to dementia.

Although the evidence is less compelling, physical activity and perhaps vitamin B_12_ plus folic acid may also show potential benefit. While the majority of the results for physical activity showed little to no effect, the percent of results showing benefit in cognitive performance, particularly in resistance training and aerobic exercise, were unlikely to be explained solely by chance. Results for B_12_ and folic acid are more spotty and so less persuasive; vitamin B_12_ and folic acid showed benefit in brief cognitive test performance and memory, but not for executive/attention/processing speed. There were also conflicting findings for B_12_ when used in combination with other B vitamins.

Notably, not all risk factors of interest were addressed by the eligible literature sufficiently for an assessment of these strategies to be made. For example, obesity is a risk factor of concern but it can be studied only in the context of prevention/intervention by assessing the impact of weight loss interventions. In the current systematic review, only one medium risk of bias trial specifically targeted weight loss. Some classes of interventions of interest were absent from the literature altogether, including interventions aimed at depression, smoking cessation, or community-level interventions. Other intervention types were represented by a literature set that was relatively sparse and likely did not represent a full range of possible interventions designs, such as sleep interventions. Lastly, with respect to the stroke prevention literature, although this study included the literature relevant to the vascular components of mixed dementias, it deliberately excluded clear post-stroke dementia. Thus, the findings may underestimate the effects of controlling blood pressure on dementias as a whole.