# 5 Discussion

Research on interventions to prevent or slow age-related cognitive decline, mild cognitive impairment (MCI), or clinical Alzheimer’s-type dementia (CATD) has focused largely on their effect on decline in measures of cognition. The reasons for this are many, including 1) meaningful investigation of dementia-onset requires either a long followup period or a large cohort of older individuals, 2) long followups in the target population face serious attrition problems due to death or comorbidities, and 3) the risk of selective attrition whereby the intervention might also affect mortality risk and hence create attrition bias if survivors have more health problems.

Interventions to slow or prevent age-related cognitive decline, MCI, or CATD are often chosen because of evidence from epidemiological studies that examine actions of individuals at higher or lower than expected risk for these conditions. In other cases, theories of brain function (e.g., neuroplasticity) justify the development and testing of experimental interventions. Not all such interventions would be expected to be found to be effective in controlled experiments. This systematic review cast a wide net and only a few interventions showed any evidence of an effect, all of which raise many questions. Most of the studies showed no benefit to those receiving interventions compared to control groups. Four intervention classes show some positive results and seem the most promising for further study: cognitive training, physical activity, the selective estrogen receptor modulator (SERM) raloxifene, and B_12_ plus folic acid, although the evidence for raloxifene and B_12_ plus folic acid is lower than the others. The problems with study designs make strong conclusions difficult. Assessing the strength of evidence for negative findings is a special challenge. There is a persistent concern about Type II errors.

The studies used a wide variety of instruments to assess cognitive performance. To facilitate analysis and interpretation, we categorized tests and measures into four groups (brief cognitive test performance, multidomain neuropsychological performance, executive function/attention/processing speed, and memory); some tests fit into more than one of these four groups.

## Dementia Incidence

Cognitive decline is almost always a precursor of dementia. Impairment below a designated threshold helps to define CATD and/or MCI. But not all individuals with cognitive decline develop CATD, and we do not know whether interventions that show effects on selected areas of cognitive performance can also stave off dementing conditions. Presumably, the broader the effect an intervention has on multiple cognitive domains, the more likely it will also have preventive effects. But improving (or slowing the decline of) performance in one given cognitive domain does not automatically imply protection against dementia. For example, some cognitive training does seem to improve performance in the specific area of the training, but the results do not generalize to improved performance in other cognitive domains. The strongest effect of cognitive training found in this analysis was in enhancing processing speed, but extrapolating that benefit to a reduced risk of CATD is not yet established. For example, improving a person’s useful field of vision can help with driving a car, and it might facilitate some instrumental activities of daily living (IADLs), but neither of those benefits necessarily slows the onset of CATD.

Unfortunately for our review, the largest and longest study of prevention of cognitive decline, the ACTIVE trial, was designed to enhance and monitor changes in specific areas of cognitive performance, but not the incidence of CATD. Efforts to adapt the ACTIVE trial to this important outcome were challenging; there was substantial attrition and the CATD diagnosis measures were weak. The measures related to diagnosis of CATD were developed late in the study and relied on either simple clinical measures or reports from family about cognitive problems or institutionalization. The analyses used did not overcome these problems.

Other interventions do show some benefit in slowing dementia, although the results are mixed at best. What explains the variation in results? To help explore possible answers to this question, and later issues regarding the results for cognitive performance, we provide some summary figures that are intended to provide a bird’s-eye view of the results detailed in the previous chapters. The figures do not provide detailed information on the specifics of the findings or the assessed strength of evidence. Instead, they show patterns of nonsignificant findings and significant findings that benefit either the intervention or the control groups. Table 5.1 provides a key to interpret the sample size from the symbol size. Different symbols are used to represent different outcomes in the figures. Circles show significant effects favoring interventions. Diamonds and X’s show non-significant results for dementia only or composite of dementia or MCI respectively. Squares show incidences when the intervention favors the controls. One symbol is assigned for every reported outcome; if a single study reported multiple outcome measures or tests for a give outcome, multiple symbols will be assigned. For example, if three different tests for memory were used by a single study, three symbols will be assigned to the memory category.

Table 5.1 Symbol sizes and related sample size information

Table 5.1 functions as a reference for Figures 5.2 through 5.6. Figures 5.2 through 5.6 use symble shapes and sizes to represent different outcomes and the sample size of the studies that sourced those outcomes. Sample sizes ranged from a small size of less than 100 participants to very large studies of over 15,000 participants.

Symbol Sizes Used | Sample Sizes Represented
| N<100
| N=100–500
| N=501–1,000
| N=1,001–5,000
| N=5,001–10,000
| N=10,001–15,000
| N=15,000+

N=sample size

Figure 5.1 summarizes the findings on the range of interventions aimed at reducing the incidence of dementia or MCI. The preponderance of studies showed no effect. In the case of estrogen therapy, the control groups did better than the experimental groups for dementia or composite dementia or MCI, suggesting a de facto harm. This is in contrast to the improvement in MCI alone for SERM (not shown in Figure 5.1).

Figure 5.1 Summary: Dementia or MCI incidence by intervention type

Figure 5.1 displays a summary of reported dementia incidence in each intervention category for both individuals with normal cognition and MCI. Across all of the intervention categories, 37 measures of incident dementia found no statistically significant differences between intervention and control groups. Only studies on cognitive training, physical activity, and antihypertensives reported statistically significant differences in incident dementia that favored the intervention (a total of 4 measures). Studies in the hormone therapy intervention categories reported statistically significant differences in incident dementia that favored the control (a total of 2 measures).

Maintaining a long followup cohort is difficult, but important in any future research examining potential interventions that could slow or prevent dementia. In addition to long followup periods, studying the incidence of dementia requires that attrition be minimized. Attrition bias presents challenges similar to those associated with selection bias. However, with attrition, investigators have more information about the dropouts, and those data could permit better modeling to assess its potential impact. Subjects who drop out because of functional reasons should be evaluated for cognitive status. Death will play a censoring role, but analyses can explore its role in attrition bias because a larger pool of variables is available for modeling. The rate of dementia incidence will increase with age. Starting with an older cohort will facilitate accumulating cases with less attrition, but it will make it more difficult to ascertain the relationship between the intervention and subject age.

## Cognitive Performance

Cognitive training studies were dominated by the ACTIVE trial, which investigated the effects of different types of group-based cognitive training on various cognitive performance outcomes for presumably cognitively healthy participants. For the most part, the training had sustained effects (up to 2 years) on cognitive performance in the domain trained but there was little evidence of generalization to other cognitive domains. There was an effort to assess the effects of booster training, but assignment to receive a booster was not random; participants with high initial compliance received most of the boosters.

As shown in Figure 5.2, the ACTIVE study showed mixed effects. For example, across different outcomes in the memory training, one test result found significant benefit with the intervention and two did not. The positive results were in the training domain and one instance of spillover/transfer to an alternate domain. Memory did not show a statistical effect at 10 years. Otherwise the nonsignificant results were for domains not trained, showing generally a lack of generalization/transfer across domains.

Figure 5.2 Summary of the tests of cognitive performance: results of ACTIVE trial

Figure 5.2 displays a summary of the cognitive performance results of the ACTIVE trial, which had 2,832 participants. At 2-year followup, participants in the intervention arms (memory, reasoning, or processing speed training) showed statistically significant improvements in 1 of 3 measures of memory, 1 of 3 measures of reasoning, and 1 of 3 measures of processing speed. At the 5-year follow up period, participants in the intervention arms showed statistically significant improvements in 1 of 3 measures of memory, 2 of 3 measures of reasoning, and 1 of 3 measures of processing speed. In addition, there were no statistically significant differences between intervention and control groups in dementia diagnosis at 5-year followup. At 10-year followup, participants in the intervention arms showed statistically significant improvements in 1 of 3 measures of reasoning and 1 of 3 measures of processing speed. No statistically significant differences were observed for the memory outcome.

The other cognitive training trials showed basically the same pattern (See Figure 5.3).

Figure 5.3 Summary of the tests of cognitive performance from additional cognitive training trials other than ACTIVE for adults with normal cognition

Figure 5.3 displays a summary of tests of cognitive performance for additional cognitive training trials (not the ACTIVE tiral) in individuals with normal cognition Five studies with a total of 1,441 subjects reported 38 measures of executive, attention, and processing speed, 21 of which showed statistically significant differences favoring the intervention. The studies also reported 10 measures of memory, five of which showed statistically significant differences favoring the intervention.

The predominant pattern of the intervention studies is one of no benefit at either the cognitive domain or the dementia level. Some of this absence of effect might be attributed to inadequate statistical power, but many studies were adequately powered. Ideally, the smaller studies might be entered in a meta-analysis, but the wide variety of tests employed forced us to work at the domain level, which, as mentioned, precluded a meta-analyses. We were able to calculate Cohen D’s for some of the studies but were still unable to meaningfully pool the data.

Among participants with MCI, the findings are less impressive and rely on small studies. (See Figure 5.4.) Note that two reports (of the same small number of participants), Buschert 2012 & Forster 2011, addressed multiple outcomes.

Figure 5.4 Summary of the tests of cognitive performance from additional cognitive training trials other than ACTIVE for adults with MCI

Figure 5.4 displays a summary of tests of cognitive performance for additional cognitive training trials (not the ACTIVE trial) on individuals with MCI. Five studies with a total of 438 subjects reported one measure of diagnosis and one biomarker, both of which showed a statistically significant difference favoring the intervention. The studies also reported one measure of brief cognitive test performance which showed no statistically significant difference between the intervention and control. However, one measure of and one measure of multidomain neuropsychological performance was significant. Of the 14 measures of executive, attention, and processing speed, two showed statistically significant differences favoring the intervention. Four of 21 measures of memory showed statistically significant differences favoring the intervention.

Aerobic and resistance training provided the highest proportion of significant positive results among physical activity interventions. Figure 5.5 summarizes the results of these studies. It is organized by type of exercise and cognitive domain assessed. As a result, the same studies appear multiple times. As seen in the figure, while the majority of results showed no significant difference, the pattern of results across very different types of physical activity interventions provides an indication of effectiveness of physical activity and raises questions about whether the effect is due to physical activity per se. Resistance training appears to have little in common with aerobic exercise, but studies of both have produced some positive results. The underlying logic linking exercise to cognitive function presumed some sort of physiological effect on blood supply or stimulation of naturally occurring chemicals. Given that many of these physical activity intervention studies enrolled older sedentary adults and had followup times as short as 6 months, substantial benefits to cognition might be unlikely. However, if physical activity lowers risk for cognitive decline and CATD and interventions can be effectively implemented to change behaviors, these interventions likely involve long-term investment and may need to begin earlier in the aging process. Also, the different types of exercise showing some effect causes us to reconsider the underlying mechanisms. For example, could the effect lie in some form of socialization associated with the exercise, which could also explain positive effects of group-based cognitive training, but not similar training done alone? None of the interventions show an overwhelming or consistent effect, but one cannot ignore the positive results. Aerobic and resistance training appears to offer the greatest promise for further research of the effects of physical activity.

Figure 5.5 Summary of the tests of cognitive performance for physical activity versus inactive comparisons for adults with normal cognition

Figure 5.5 displays a summary of tests of cognitive performance for physical activity interventions versus inactive comparisons in subjects with normal cognition. Four studies with a total of 1,885 subjects examined multicomponent physical activity. Measures of brief cognitive test performance, executive, attention, and processing speed, and memory (a total of 3 measures) showed statistically significant differences favoring the intervention. The remaining 22 measures of cognitive performance were not statistically significant. Three studies with a total of 192 subjects examined resistance training. Eight of 25 measures of executive, attention, and processing speed, and 3 of 11 measures of memory showed statistically significant differences favoring the intervention. Six studies with 469 subjects examined aerobic training. Of the 28 reported measures, 11 showed statistically significant differences favoring the intervention in the areas of diagnosis (1 measure), brief cognitive test performance (1 measure), multidomain neuropsychological performance (1 measure), executive, attention, and processing speed (2 measures), and memory (6 measures). Three adverse events were also noted. One study with 93 subjects examined tai chi. One of two measures of executive, attention, and processing speed showed statistically significant differences favoring the intervention.

While the overall findings for the remaining interventions described in Chapters 4C through 4M showed little benefit, several studies of the treatment of hypertension showed improved cognitive functioning. Given that hypertension control is already a goal for the treatment of cardiovascular disease, these positive outcomes can be viewed as a potential additional benefit from efforts to control blood pressure. Ironically, if the hypertensive treatment lowered mortality, its benefits for dementia might be underestimated because of selective attrition.

Vitamin B_12_ and folic acid also showed benefit in brief cognitive test performance and memory, but not for executive/attention/processing speed. There were also conflicting findings for B_12_ when in combinations with other B vitamins. The other vitamins had no substantial benefit on cognition. Little or no benefit for cognitive performance was shown for multivitamins, vitamin C, vitamin D with calcium, or beta carotene (all low strength of evidence). Vitamins work differently if given to a person to address an insufficiency compared to a megadose for a person with otherwise adequate basic vitamin intake. The participants varied widely in this and other respects. In the case of B_12_, large doses would be needed to overcome malabsorption of this vitamin for people with high homocysteine levels.

## Methods Issues

For the vast majority of studies showing no significant effect, we need to separate the potential of small sample sizes from a true lack of effect. Ideally, meta-analysis would make use of many small studies to show an overall pattern, but the populations, interventions, and outcomes assessed were heterogeneous. At best, the categories of cognitive performance were composed of different types of tests and aggregating across domains is not appropriate methodologically.

Although we cannot say with certainty that many interventions definitely have no effect, it seems unwise to prioritize future research in areas that show little promise, such as vitamin E, nonsteroidal anti-inflammatory drugs (NSAIDs), statins, and antidiabetic treatment. The argument around antihypertensive treatment is different. Some studies showed benefit and some benefit may be underestimated because of excluding post-stroke dementia studies, but given the extant commitment to blood pressure reduction further studies of its role in preventing dementia should have lower priority than areas less endorsed currently.

Applying strength of evidence criteria to largely negative studies poses challenges. The goal of rating strength of evidence is to assess the level of confidence in the findings. How comfortable can we be that the negative results would not be overturned with further research? Some of the core elements of strength of evidence are not as helpful for studies that show no effect. Effect size is obviously zero. We can look at risk of bias and consistency. Precision can be examined to some degree, but the crux of the problem is estimating the uncertainty of the Type II error. Studies that show no effect differ from non-inferiority studies, which compare effects of two interventions. Both require looking for Type II errors, which necessitates larger sample sizes than Type I errors.

A separate issue concerns the interpretation of small effect sizes. All but a few of the results showed small changes in scores expressed as a proportion of the score range. In some cases clinicians have determined what constitutes a clinically important difference, but these are typically cast in terms of a given patient’s progress as opposed to the differences in means of study groups.

In deciding what studies warranted strength of evidence rating, we determined not to rate single studies that tested a specific intervention/outcome pair if the total sample was less than 500. As shown in Table 5.2, these eliminations would have little potential effect on the pattern of findings.

Table 5.2 Findings from smaller single studies for which strength of evidence was not assessed, by intervention type

Interventions | Number of Findings without Strength of Evidence Rating; Finding Not Reported
Antidementia | 0
Antidiabetic | 0
Antihypertensive | 0
Statins | 0
NSAIDs | 0
Hormone Therapies | 3: 1 for healthy participants NS; 2 for MCI—testosterone 1 of 14 tests favor I; soy 1 of 6 tests favors I
Vitamins | 2 (both MCI)—vitamins E+C NS; B vitamins 2 of 6 tests favor I
Nutraceuticals | 6: for healthy participants Omega 3 (biomarkers) 1 of 2 favors I; resveratrol 5 of 15 tests favor I; plant sterols/stanols NS. For MCI Omega 3 4 of 9 favor I; ginkgo biloba diagnosis NS, executive function 2 of 2 favor I
Diet | 3: for global cognition 1/1 favors I; for memory 2 studies NS
Physical Activity | Multicomponent Physical Activity multidomain composite 2 of 2 favor I; executive function 1 of 2 favor I; memory 1 of 2 favor I

MCI=mild cognitive impairment; I=intervention; NS=no statistically significant difference

In the text, we comment on the studies with risk of bias that were not analyzed. Again, including them would not change the pattern of our findings.

Many limitations arose from the available literature on this topic. A large number of the eligible studies evaluating the effectiveness of interventions in preventing incidence of MCI or Alzheimer’s disease had relatively short durations and followups, although the expected latency period to reach clinical MCI and Alzheimer’s disease and even intermediate cognitive outcomes may be quite long in younger adult populations. Consequently, short-term studies are inadequate to test effectiveness of interventions to prevent these outcomes. At best, they offer some indirect evidence. Studies with longer durations and followup may experience different rates of mortality and loss to followup between intervention and comparison participants that result in biases in missing data and confound interpretation about the effectiveness of the interventions.

Cognitive outcomes were assessed with a wide array of neuropsychologic tests. Some studies tested effects using several different tests over several time periods without any correction for multiple comparisons. Additionally, many studies tested participants at intervals not considered adequate for repeated applications of those tests. Although the specific length of the re-test gap may vary with the test, many opportunities for practice effects occurred.

## Types of Studies

This review was open to three types of studies:

1. Purposefully developed trials: intervention trials designed to address slowing or preventing age-related cognitive decline, MCI, or CATD
2. Add-on trials: trials of an intervention originally targeted at another outcome (e.g., hypertension) to which a cognitive outcome was appended, and
3. Prospective cohort studies: studies that categorized but do not assign an intervention; these frequently rely on self-reported outcomes. (Unfortunately, no studies of this type that used analytic tools to simulate quasi-experimental design and address selection bias in order to test causality were identified in the searches.)

In general, one might expect that the more stringent the design, the less often positive results were seen. The add-on studies (Type 2 above) frequently used less sophisticated measures and had no baseline values. The cohort studies typically had vague measures of exposure to the intervention which was not randomly assigned and hence subject to confounding. The quality of the outcome measures varied.

Baseline cognitive status was not carefully ascertained. While some studies collected baseline cognitive function as part of their design, others paid much less attention. They typically described participants in vague terms such as “normal” or “presumed healthy.” In some cases, participants were described as having cognitive complaints but no diagnosis.

## Value of Biomarkers

The evidence synthesis of measures of biomarkers and cognitive function introduces two important, related challenges. One is understanding the relationship between these outcomes and MCI or dementia incidence. Without a clear understanding of this relationship, it is difficult to interpret findings from short-term studies reporting only biomarkers or cognitive performance.

Biomarkers may have two levels of correlation with more clinical outcomes.

1. They may simultaneously reflect the outcome of interest.
2. They may predict a subsequent change in the outcome interest.

The biomarker measures we encountered were either used alone or in parallel with other outcomes. We limited our analysis of the agreement of biomarkers (primarily magnetic resonance imaging (MRI) and positron emission tomography (PET) scans) to their ability to distinguish outcomes in experimental and control groups.

The role of biomarkers as intermediate outcomes is unclear. Our results show a low level of agreement between the biomarker measures (which were primarily some form of brain scan) and various cognitive tests. The field of biomarkers is expanding rapidly. There has been growing concern about the analytic methodology in one of the more common types of biomarker measures, functional MRI, related to frequent lack of adjustment for large numbers of comparisons.^294^ More needs to be known about their ability to predict the clinical course of persons with various levels of cognitive function.

## Limitations of the Review Process

This review encountered several limitations, including but limited to those stemming from the topic and our approach to address it. For example, (as requested by the National Institute on Aging, NIA) we deliberately excluded dementias with specific and clear etiologies, including stroke. By doing so, we may underestimate the importance of hypertension treatment. In addition, many outcomes of interest were inconsistently defined in the literature and there were numerous and widely varied interventions to address those outcomes. Other limitations arose from conceptual and methodologic issues with eligible studies. These included sample size, length of followup, measurement issues, and attrition. Our search strategy was challenging to design given the wide range of interventions and types of studies measuring cognitive outcomes as secondary outcomes. We designed a strategy to capture a wide variety of intervention types and outcomes with a degree of precision making the review process feasible and efficient. The scale and scope of the topic made identifying all relevant studies extremely difficult. We addressed this by supplementing our bibliographic database searches with citation searches.

To address the multiplicity of cognitive performance tests used, we clustered tests into domains. Because these domains were composites of various tests with different scoring systems, meta-analysis proved unwieldy to conduct. Instead we opted to simply show the proportion of tests. We did use forest plots in some instances and calculated Cohen’s D when appropriate. While it would be possible to create a standardized score for each cognitive performance test and ultimately for each domain, we would be concatenating summary measures; such a level of abstraction would likely diminish the value potentially gained from artificially increasing the sample sizes.

As noted earlier, assessing and interpreting the strength of evidence for many studies that showed no difference was difficult, especially when we were unable to use meta-analysis to address small sample size issues. Several reviewers urged a clear distinction between the absence of strong evidence of an effect and strong evidence of no effect. We have tried to make that distinction whenever feasible.

Searches were difficult because key words could only identify studies that assessed cognitive performance outcomes as secondary outcomes if the study abstract listed the cognitive performance outcomes. Finding a balanced set of articles in cohort and add-on studies was difficult because the results were more likely to be noted in abstracts if they were positive.