# 4N Results: Agreement of Biomarkers and Measures of Cognitive Performance

## Key Messages

- Only a few (9) low or medium risk of bias studies used biomarker measures; most of those used some form of brain scan.
- The overall rate of agreement between biomarker measures and cognitive testing was 57 percent, but 90 percent of that agreement resulted from both approaches showing no effect. When the biomarker measure showed a significant result, there was agreement in 25 percent of cognitive tests conducted.

## Association Between Biomarkers and Cognitive Tests

Substantial work has gone into searching for biomarkers in living persons that indicate the level of dementia activity.^292^ In most cases, the biomarkers are validated by comparing the measure with a systematic clinical evaluation, but in some cases the biomarker measures may predict subsequent development of cognitive decline. The distinction between biomarkers that are used as early harbingers of incipient disease vs. those that track with disease progression is important. Imaging indices are most often used as an example of the later category but not always. cerebrospinal fluid (CSF) and blood indices are commonly used as either. Biomarkers for early identification might be of interest for those interventions with people with normal cognition and less so with MCI/dementia (and NOT expected to correlate with cognition), whereas those biomarkers that are intended to track with disease progression would be the opposite – of more interest in impaired groups and more expected to agree with observable symptoms.

KQ3 compares the biomarker measure results with cognitive testing results in the studies used for KQs 1 and 2. Only a small number of studies used both biomarker measures and cognitive testing. There were 35 biomarker measures used in 9 studies. One of the studies included two treatment arms. A few studies used only biomarker measures (and were omitted from this comparison). Several other studies included biomarker measures that were assessed as high risk of bias and not included in this analysis. Few studies used the same biomarker measure. The biomarker measures used here were all based on brain scans (MRI or PET).

Table 4N.1 shows the rate of agreement between a given biomarker measure and the cognitive domains that were simultaneously tested. The overall rate of agreement was 57 percent (144/254) but the underlying result of the biomarker played a major role in agreement. Of the 23 cases where the biomarker measure was not significant, there were 197 cognitive tests of which 130 were also not significant (66 percent). Of the 12 cases where the biomarker measure was significant, there were 57 cognitive tests of which 14 agreed with the biomarker (25 percent). There was only one study in which none of the biomarker measures nor cognitive tests were significant.^93, 94^ The ability to detect a difference somewhere in the study suggests that lack of statistically significant findings was not solely attributable to small sample sizes. Nonetheless, interpreting the implications of agreement when both approaches failed to detect a difference is challenging.

Table 4N.1 Summary of agreement between biomarkers and cognitive tests

Biomarker | Biomarkers | Diagnosis | Dementia Screens^*^ | Executive/Attention/Processing Speed | Memory | Agreement Rate | Intervention
MRI-grey matter volume | I>C | | | I>C, NS, NS | NS | 1/4 | Omega 3^117^
MRI-grey matter volume | NS | | | | I>C, I>C, NS, NS, NS, NS | 4/6 | Resveratrol^118^
MRI-white matter integrity | NS | | | I>C, NS, NS | NS | 3/4 | Omega 3^117^
MRI-HC microstructure | NS | | | | I>C, I>C, NS, NS, NS, NS | 4/6 | Resveratrol^118^
MRI-HC frontal | I>C | | | | I>C, I>C, NS, NS, NS, NS | 2/6 | Resveratrol^118^
MRI-HC parietal | I>C | | | | I>C, I>C, NS, NS, NS, NS | 2/6 | Resveratrol^118^
MRI-HC occipital | I>C | | | | I>C, I>C, NS, NS, NS, NS | 2/6 | Resveratrol^118^
MRI-total brain volume | NS | C>I, NS, NS | C>I | NS, NS, NS | NS, NS, NS, NS, NS | 10/12 | Estrogen^149, 175, 177, 178, 180, 293^
MRI-total brain volume | NS | C>I, NS, NS | C>I | NS, NS, NS | C>I, C>I, C>I, C>I, NS | 6/12 | Estrogen+ progestin^149, 151, 175, 177–179^
MRI-total brain volume | I>C | | NS | NS, NS | NS | 0/4 | Glycemic control^280, 282^
MRI-ventricular volume | NS | C>I, NS, NS | C>I | NS, NS, NS | NS, NS, NS, NS, NS | 10/12 | Estrogen^149, 175, 177, 178, 180, 293^
MRI-ventricular volume | NS | C>I, NS, NS | C>I | NS, NS, NS | C>I, C>I, C>I, C>I, NS | 6/12 | Estrogen+ progestin^149, 151, 175, 177–179^
MRI-HC volume | NS | C>I, NS, NS | C>I | NS, NS, NS | NS, NS, NS, NS, NS | 10/12 | Estrogen^149, 175, 177, 178, 180, 293^
| NS | C>I, NS, NS | C>I | NS, NS, NS | C>I, C>I, C>I, C>I, NS | 6/12 | Estrogen+ progestin^149, 151, 175, 177–179^
MRI-whole brain cortices | NS | | NS, NS | | NS, NS | 4/4 | Multicomponent physical activity^93, 94^
MRI-medial temporal areas, including entorhinal cortex | NS | | NS, NS | | NS, NS | 4/4 | Multicomponent physical activity^93, 94^
Left HC volume | NS | | NS | I>C | I>C, NS | 2/4 | Statins^248^
Right HC volume | NS | | NS | I>C | I>C, NS | 2/4 | Statins^248^
MRI-frontal lobe volume | C>I | C>I, NS, NS | C>I | NS, NS, NS | NS, NS, NS, NS, NS | 2/12 | Estrogen^149, 175, 177, 178, 180, 293^
MRI-frontal lobe volume | NS | C>I, NS, NS | C>I | NS, NS, NS | C>I, C>I, C>I, C>I, NS | 6/12 | Estrogen+ progestin^149, 151, 175, 177–179^
Abnormal white matter | C>I | | NS | NS, NS | NS | 0/4 | Glycemic control^280, 282^
White and grey matter | NS | C>I, NS, NS | C>I | NS, NS, NS | NS, NS, NS, NS, NS | 10/12 | Estrogen^149, 175, 177, 178, 180, 293^
White and grey matter | NS | C>I, NS, NS | C>I | NS, NS, NS | C>I, C>I, C>I, C>I, NS | 6/12 | Estrogen+ progestin^149, 151, 175, 177–179^
Basal ganglia | NS | C>I, NS, NS | C>I | NS, NS, NS | NS, NS, NS, NS, NS | 10/12 | Estrogen^149, 175, 177, 178, 180, 293^
Basal ganglia | NS | C>I, NS, NS | C>I | NS, NS, NS | C>I, C>I, C>I, C>I, NS | 6/12 | Estrogen+ progestin^149, 151, 175, 177–179^
Total brain lesion volume | NS | C>I, NS, NS | C>I | NS, NS, NS | NS, NS, NS, NS, NS | 10/12 | Estrogen^149, 175, 177, 178, 180, 293^
Total brain lesion volume | NS | C>I, NS, NS | C>I | NS, NS, NS | C>I, C>I, C>I, C>I, NS | 6/12 | Estrogen+ progestin^149, 151, 175, 177–179^
Posterior atrophy | I>C | | NS | | NS | 0/2 | Vitamin B^195^ ^194, 207^
Left amygdala volume | I>C | | NS | I>C | I>C, NS | 2/4 | Statins^248^
Right amygdala volume | NS | | NS | I>C | I>C, NS | 2/4 | Statins^248^
White matter lesion volume | NS | | NS | I>C | I>C, NS | 2/4 | Statins^248^
Glucose uptake (PET scan) | I>C | I>C | I>C, NS | NS, NS | I>C, NS | 3/7 | Cognitive training^48, 49^
Amyloid-beta | I>C | NS | | | | 0/1 | Lithium^289^
Phosphorylated tau at threonine | I>C | NS | | | | 0/1 | Lithium^289^
Total tau | NS | NS | | | | 1/1 | Lithium^289^
Overall agreement rate | | | | | | 144/254 (57%)
Agreement based on both showing no significant pattern of effect (NS) | | | | | | 130/197 (66%)
Agreement rate when the biomarker showed a significant difference | | | | | | 14/57 (25%)

* Includes both brief tests of cognitive performance and multidomain neuropsychological performance tests

C=control; HC=hippocampus; I=intervention; NS=no statistically significant difference

We used a simple calculation of agreement rates between each biomarker measure and the cognitive tests used in a study to distinguish differences between experimental and control participants. For example, in a study of omega-3 fatty acids,^117^ grey matter volume was found to be decreased in those receiving the intervention compared to the controls. In one instance (a test of executive function/attention/processing speed) the cognitive test showed a similar pattern. In two other measures of executive/attention/processing speed and a memory test, it did not. Hence the rate of agreement for a finding of biomarker difference in this case was 1/4. Similarly, when the grey matter volume showed no significant difference in one study of in adults receiving resveratrol,^118^ cognitive performance showed a difference in 2 out of 6 tests of cognition. Hence the agreement rate was 4/6.