# 4M Results: Other Interventions

## Key Messages

- Evidence was insufficient for lithium, a nicotine patch, individual piano instruction, multitask rhythmic exercise to music, sleep interventions, and social engagement.
- We found no relevant studies for depression treatments, smoking cessation, or community-level interventions.

## Eligible Studies

We identified nine eligible studies of other varied interventions to prevent age-related cognitive decline, mild cognitive impairment (MCI), or CATD.^72, 79, 135, 286–291^ Five studies for adults with normal cognition^79, 286–288, 291^ and one for adults with MCI^72^ were assessed as high risk of bias and thus are discussed only briefly. Appendix R provides evidence tables and summary risk of bias assessments.

## Adults With Normal Cognition

Hars et al. (n=134) examined the effects of a weekly 1 hour supervised group class in which participants performed multitask exercises to rhythmic music versus inactive control in adults ≥65 years who were at increased risk of falling. After 6 months, no significant differences in Mini-Mental State Examination (MMSE) scores or executive function were observed.^135^ Adverse events were not reported. Table 4M.1 summarizes results. A conclusion table is not provided since evidence was insufficient due to limited data (single study n<500).

Table 4M.1 Results overview: Other intervention in adults with normal cognition

Author Year Comparison N= Followup | Diagnosis | Biomarkers [specific biomarker] | Brief Cognitive Test Performance/Multidomain Neuropsychological Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
Music Intervention Results Summary k=1; n=134 | | | BCT 0 of 1 (no difference) k=1 | 0 of 2 (no difference) k=1 | | 0 of 3 (no difference)
Hars, 2014^135^ Weekly 1 hour supervised group class; multitask exercises to rhythm n=134 6 months | | | BCT NS [MMSE] | NS [CLOX-1] | | 0 of 3 (no difference) | NR
Hars, 2014^135^ Weekly 1 hour supervised group class; multitask exercises to rhythm n=134 6 months | | | | NS [FAB]

BCT=brief cognitive test; CLOX-1=Clock Drawing Test; FAB=Frontal Assessment Battery; k=number of studies included; MMSE=Mini-Mental Status Examination; n=sample size; NR=not reported; NS=no statistically significant difference.

Shading indicates summary rows and columns.

The remaining five studies with adults with normal cognition were high risk of bias. Interventions examined in these studies included: individualized piano instruction for musically naïve older adults (n=31, 9 month followup);^288^ personalized sleep plans to extend sleep for obese adults who sleep for shorter periods (n=121, 14 month followup);^286^ transcranial random noise stimulation (n=25, 6 month followup);^291^ guided progressive muscle relaxation tapes to improve sleep in older adults with reduced sleep quality (n=80, 12 months);^287^ and group social interaction for 1 hour three times per week at a neighborhood community center for older adults (n=276, 40 weeks).^79^

## Adults With MCI

Table 4M.2 summarizes results for two medium risk of bias studies of adults with MCI. A conclusion table is not provided since evidence was insufficient due to limited data (single study n<500).

Table 4M.2 Results overview: Other intervention in adults with MCI

Author Year Comparison N= Followup | Diagnosis | Biomarkers [specific biomarker] | Brief Cognitive Test Performance/Multidomain Neuropsychological Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
Other Medications Results Summary k=2; n=108 | 0 of 1 (no difference) k=1 | 2 of 3 favor I k=1 | NR | Unclear | NR | 2 of 3 favor I
Newhouse, 2012^290^ Nicotine patch 15 mg/day vs. placebo n=67 6 months | | | | Selective outcome reporting | | | NS [No severe AEs classified as related to drug treatment]
Forlenza, 2011^289^ Lithium titrated to serum levels 0.25–0.5 mmol/l vs. placebo n=41 1 year | NS [Conversion to Probable AD] | I>C [Amyloid-Beta] | | | | | NS [Ischemic stroke, death due
Forlenza, 2011^289^ Lithium titrated to serum levels 0.25–0.5 mmol/l vs. placebo n=41 1 year | | NS [Total Tau] | | | | | to sepsis; neither
Forlenza, 2011^289^ Lithium titrated to serum levels 0.25–0.5 mmol/l vs. placebo n=41 1 year | | I>C [Phosphorylated Tau] | | | | | deemed due to treatment]

AD=Alzheimer’s Disease; AEs=adverse effects; C=control; k=number of studies included; I=intervention; mg/day=milligrams per day; mmol=millimole; n=sample size; NR=not reported; NS=no statistically significant difference; vs.=versus.

Shading indicates summary rows and columns.

Forlenza et al. (n=45) examined the effects of lithium versus placebo in adults at least 60 years old with amnestic MCI as assessed by the Mayo criteria.^289^ Dosage was titrated to a level below that used for affective disorders to avoid problems of tolerability. No difference in conversion to Alzheimer’s dementia was found after 12 months. The lithium group showed improvement in amyloid-beta and phosphorylated tau but not total tau when compared to placebo. The study found no severe adverse events deemed related to the treatment.

Newhouse et al. (n=74) examined the effects of transdermal nicotine patches in non-smoking adults at least 55 years old with probable MCI.^290^ Numerous cognitive performance tests were assessed as secondary outcomes at 6 months, however not all outcomes were reported as tests of differences between groups, so the possibility of selective outcome reporting was high.^290^ The study found no severe adverse events deemed related to the treatment.

One other study with high risk of bias examined cognitive group social interaction (board games, reading/discussing newspapers) at least three times per week for 1 hour in adults with MCI (n=276, 12 months).^72^