# 4L Results: Diabetes Medication Treatment

## Key Messages

- No studies reported on the effect of diabetes treatment on the risk of incident clinical diagnoses of mild cognitive impairment (MCI) or clinical Alzheimer’s-type dementia (CATD)^*^
- In middle-aged older adults with diabetes and presumed normal cognition, low-strength evidence shows intensive versus standard glycemic control had no significant effect on cognitive performance.

## Eligible Studies

We identified eight eligible studies that compared diabetes medication treatment versus control treatment to prevent age-related cognitive decline, MCI, or CATD.^67, 120, 277–282^ We rated three of these studies as having high risk of bias and excluded them from our analyses.^278, 279, 281^ The remaining five studies (four unique trials) enrolled a total of 15,672 adults.^67, 120, 280, 282^ Appendix Q provides evidence tables, summary risk of bias assessments, and assessments of strength of evidence for key comparisons and outcomes.

## Logic of Diabetes Medication Treatment

A recent meta-analysis of prospective cohort studies estimated that the presence of a diabetes diagnosis between the ages of 20 to 79 years increased the risk of incident CATD by nearly 50 percent.^283^ Diabetes may increase risk of Alzheimer’s disease through vascular mechanisms, direct effects of elevated blood glucose, insulin resistance associated inflammation, and/or a pathway in which peripheral hyperinsulinemia inhibits brain insulin production, which then results in impaired brain amyloid clearance.^242^

## Adults With Normal Cognition

Two trials, the ACCORD-MIND and the ORIGIN studies, addressed persons with presumed normal cognition but only the ACCORD-MIND study specifically reported excluding participants with preexisting clinical evidence of dementia.^284^ Both trials addressed persons at high risk for cardiovascular events; both compared intensive and standard glucose control for diabetics, and both were large substudies. The ACCORD-MIND trial enrolled 2,977 older adults.^280, 282^ The ORIGIN study randomized 12,537 older adults.^285^ The publication provided no information about how normal cognition was defined and did not report any cognition-related exclusion criteria. Conclusions are reported in Table 4L.1 and individual study results in Table 4L.2.

Table 4L.1 Conclusions: Antidiabetic interventions in adults with normal cognition

Comparison | Outcome | Conclusion | Strength of Evidence (justification)
Glycemic control vs. placebo k=2 | Dementia | No statistically significant difference in dementia diagnoses with glycemic control versus placebo (n=12,537; 6 years). | Low (due to study limitation of composite outcome with component of unequal importance, one of which is not clinical diagnosis and may be achieved due to chance)
Glycemic control vs. placebo k=2 | MCI | No data available. | Insufficient (no data)
Glycemic control vs. placebo k=2 | Brief cognitive test performance | A 40-month trial and a 6-year trial found no statistically significant differences in brief cognitive test performance in glycemic control versus placebo (n=15,514; up to 6 years). | Low (medium study limitations, indirect, imprecise)
Glycemic control vs. placebo k=2 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
Glycemic control vs. placebo k=2 | Executive/Attention/Processing speed | A 40 -month trial and a six year trial found no statistically significant difference in executive function, attention, and processing speed with glycemic control versus placebo (n=15,514; up to 6 years). | Low (medium study limitations, indirect, imprecise)
Glycemic control vs. placebo k=2 | Memory | A 40-month trial found no statistically significant difference in memory with glycemic control versus placebo (n=2,977; 3.3 years). | Low (medium study limitations, indirect, imprecise)

k=number of studies included; MCI=mild cognitive impairment; n=sample size; vs.=versus

Table 4L.2 Results Overview: Antidiabetic interventions in adults with normal cognition

Author Year Comparison N= Followup | Diagnosis | Biomarkers [specific biomarker] | Brief Cognitive Test Performance/Multidomain Neuropsychological Test Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
Glycemic Control Results Summary k=2; n=15,514 | 0 of 1 (no difference) k=1 | 1 of 2 favor I 1 of 2 favor C k=1 | BCT 0 of 2 (no difference} k=2 | 0 of 3 (no difference) k=2 | 0 of 1 (no difference) k=1 | 1 of 8 favors I 1 of 8 favors C
ACCORD-MIND Trial Seaquist, 2013^282^ Launer, 2011^280^ Intensive glycemic control targeting HbA1c to less than 6.0% vs. standard glycemic control targeting HbA1c to 7–7.9% n=2,977 40 months | | I>C [Total Brain Volume] | BCT NS [MMSE] | NS [DSST] | NS [RAVLT] | 1 of 6 favors I 1 of 6 favors C | NS [Mortality]^a^
ACCORD-MIND Trial Seaquist, 2013^282^ Launer, 2011^280^ Intensive glycemic control targeting HbA1c to less than 6.0% vs. standard glycemic control targeting HbA1c to 7–7.9% n=2,977 40 months | | C>I [Abnormal White Matter] | | NS [SCWT]
Cukierman-Yaffe, 2014^120^ Titrated basal insulin glargine targeting a fasting plasma glucose concentration vs. standard of care n=12,537 72 months | NS [MMSE <24, or diagnosed on report forms] | | BCT NS [MMSE] | NS [DSST] | | 0 of 2 (no difference) | NR

a In February, 2008, increased mortality risk in the main ACCORD study led to the end of the intensive treatment and a transition of those participants to standard treatment.

BCT=brief cognitive test performance; C=control; DSST=Digit Symbol Substitution Test; HbA1c=hemoglobin A1c; I=intervention; MMSE=Mini-Mental Status Exam; NR=not reported; NS=no statistically significant difference; RAVLT=Rey Auditory Verbal Learning Test; SCWT=Stroop Color Word Test; vs.=versus.

Shading indicates summary rows and columns.

No study reported the outcomes of incident clinically diagnosed MCI or dementia. The ORIGIN trial found no difference after a mean followup of 6.2 years in the risk of probable incident cognitive impairment as defined by either a diagnosis of dementia on the study case report forms or a decline in followup Mini-Mental State Examination (MMSE).^120^ However, the overall ORIGIN trial reported little difference in mean HbA1C at 6 years between the intensive and standard control groups.^285^

Low-strength evidence from both trials shows no difference in change in cognitive performance between those assigned to intensive versus standard glycemic control. In the ACCORD-MIND trial, over a 40-month followup there was no difference between the groups in the mean decline in MMSE, a global measure of cognition.^280, 282^ Similarly, in the ORIGIN trial, over a mean followup of 6.2 years, there was no between-group difference in the mean annualized MMSE decline.^120^ Within specific cognitive domains, these trials reported no statistically significant difference between treatment groups for change in verbal memory,^280^ executive function,^120, 282^ attention,^280^ or processing speed.^120, 280, 282^

The ACCORD-MIND trial enrolled participants with normal cognition and measured brain MRI in a subset of participants.^280^ Among the 503 participants with followup MRIs at 40 months, those randomized to intensive glycemic control had significantly smaller declines in total brain volume, but significantly more abnormal white matter tissue volume.

The ACCORD-MIND trial reported no difference between the intensive and standard glycemic control groups in risk of mortality.^280^

## Adults With MCI

Two trials evaluated the effect of glycemic control on cognition in older adults with MCI. Hildreth et al. randomized 78 older adults with MCI, central obesity (presumed to confer insulin resistance), and no diabetes to pioglitazone versus endurance exercise training or control (placebo, no exercise) for 6 months,^67^ while Luchsinger et al. randomized 80 overweight older nondiabetic and diet controlled diabetic adults with amnestic MCI to metformin up to 1000mg twice a day versus placebo for 12 months.^277^

The Hildreth trial reported no information on the risk of CATD, but found no difference in intervention and control groups in change between baseline and 6 months in a single global measure of cognition, the cognitive domains of memory, language, visuospatial or executive function, or in any individual cognitive test.^67^ The trial did not report information on biomarker outcomes or adverse events. The trial was likely too small to detect the small changes in cognitive outcomes that might realistically be expected in its MCI population over its 6-month duration, let alone differences in these outcomes between pioglitazone and control groups.

The Luchsinger trial reported that one person in the placebo group and none in the metformin group converted to dementia.^277^ In adjusted analyses, there was no difference between groups in change from baseline in two global measures of cognition or in one measure of executive/attention/processing speed, but the metformin group had statistically significantly more improvement from baseline than the placebo group in one of two memory tests. In stratified analyses reported only for the single memory test, between group differences in the memory test were statistically significant in participants ≤63.7 but not >63.7 years old, those who were negative but not positive for APOE-4, those with hemoglobin A1c ≤6.0% but not those with >6.0%, and those with an insulin level >9 IU/dl but not those with insulin <9.0 IU/dl. There were no significant differences between treatment groups in strata defined by BMI < or ≥30 kg/m^2^. There were no significant differences between treatment groups for change from baseline in any of the brain MRI or PET measures reported, or in change in plasma Aβ42 levels.

Individual study results are provided in Table 4L.3. No conclusion table is provided given evidence was insufficient due to limited data (single study with n<500).

Table 4L.3 Results overview: Antidiabetic interventions in adults with MCI

Author Year Comparison N= Followup | Diagnosis | Biomarkers [specific biomarker] | Brief Cognitive Test Performance/Multidomain Neuropsychological Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
Pioglitazone Results Summary k=1; n=78 | | | MNP 0 of 1 (no difference) k=1 | 0 of 5 (no difference) k=1 | 1 of 4 favors I k=1 | 1 of 10 favors I
Hildreth, 2015^67^ Pioglitazone 30mg daily for 1 month, then 45mg daily as tolerated for 5 months vs. placebo n=78 6 months | | | MNP NS [ADAS-Cog] | NS [SCWT] | NS [RAVLT] | 1 of 10 favors I | NR (there were no cases of new
Hildreth, 2015^67^ Pioglitazone 30mg daily for 1 month, then 45mg daily as tolerated for 5 months vs. placebo n=78 6 months | | | | NS [TMT B] | NS [WMS, Logical Memory II] | | or worsening heart failure in the treatment group)
Hildreth, 2015^67^ Pioglitazone 30mg daily for 1 month, then 45mg daily as tolerated for 5 months vs. placebo n=78 6 months | | | | NS [DS Backward] | NS [Composite]
Hildreth, 2015^67^ Pioglitazone 30mg daily for 1 month, then 45mg daily as tolerated for 5 months vs. placebo n=78 6 months | | | | NS [DSST] | I>C [Visual Reproduction]
Hildreth, 2015^67^ Pioglitazone 30mg daily for 1 month, then 45mg daily as tolerated for 5 months vs. placebo n=78 6 months | | | | NS [Composite]
Metformin Results Summary k=1; n=80 | | 0 of 4 (no difference) k=1 | BCT 0 of 1 (no difference) k=1 MNP 0 of 1 (no difference) k=1 | 0 of 1 (no difference) k=1 | 1 of 3 favors I k=1 | 1 of 10 favors I
Luchsinger, 2016^277^ Metformin 1000mg twice daily for 12 months vs. placebo n=80 1 year | | NS [Posterior Cingulate-Precuneus Glucose Update] | BCT NS [MMSE] MNP NS [ADAS-Cog] | NS [DS] | I>C [Buschke Selective Reminding Test] | 1 of 10 favors I
Luchsinger, 2016^277^ Metformin 1000mg twice daily for 12 months vs. placebo n=80 1 year | | NS [Hippocampus Glucose Update] | | | NS [WMS-Revised, Logical Memory II]
Luchsinger, 2016^277^ Metformin 1000mg twice daily for 12 months vs. placebo n=80 1 year | | NS [Para-Hippocampus Glucose Uptake] | | | NS [Paragraph Recall]
Luchsinger, 2016^277^ Metformin 1000mg twice daily for 12 months vs. placebo n=80 1 year | | NS [Entorhinal Cortex Glucose Uptake]

ADAS-Cog=Alzheimer’s Disease Assessment Scale-Cognitive Subscale; BCT=brief cognitive test; C=control; DS=Digit Span (Forward and/or Backward); DSST=Digit Symbol Substitution Test; I=intervention; k=number of studies; MMSE=Mini-Mental Status Exam; MNP=multidomain neuropsychological test performance; n=sample size; NR=not reported; NS=no statistically significant difference; RAVLT=Rey Auditory Verbal Learning Test; SCWT=Stroop Color Word Test; TMT=Trail Making Test (Part A and/or B); vs.=versus; WMS=Wechsler Memory Scale.

Shading indicates summary rows and columns.

## Interpreting the Findings

Among included studies, there was minimal to no difference between glycemic intervention and control groups in incident cognitive impairment or change in cognitive performance in adults with normal cognition (intensive versus standard control), and minimal difference in any cognitive outcomes in adults with MCI (pharmacologic monotherapy versus placebo). Because there was no substantial change in cognitive performance tests from baseline among control group participants in the included studies, it was not possible for these studies to demonstrate whether intensive glycemic control prevents cognitive decline. However, results do not show that glycemic interventions lead to clinically meaningful improvements in cognition from baseline. Although the small difference in achieved glycemic control between treatment groups in the ORIGIN trial may have limited the ability of that study to observe a difference in cognitive outcomes, cognitive results also were not meaningfully different between treatment groups in the ACCORD-MIND trial despite the markedly improved glycemic control between their intervention and placebo groups.

* Note that the literature currently does not use the term CATD; we specified whenever the diagnosis of dementia was defined.