# 4K Results: Antidementia Drugs

## Key Messages

- Low-strength evidence shows acetylcholinesterase inhibitor (AChEI) antidementia drugs did not reduce the incidence of clinical Alzheimer’s-type dementia (CATD)^*^ in persons with mild cognitive impairment (MCI); evidence is insufficient for persons with normal cognition.
- Low-strength evidence shows AChEIs provide no significant effect on cognitive performance in adults with MCI.

## Eligible Studies

We identified 13 eligible publications involving 10 unique studies of antidementia drugs to prevent age-related cognitive decline, MCI, or CATD.^203, 213, 263–272^ All but two studies (and an additional outcome from a third study) were assessed as high risk of bias and not used in our analysis.^264–268, 270, 272, 273^ All interventions used in the studies included in the analysis were AChEIs. We analyzed the efficacy of these drugs for adults with normal cognition and those with MCI separately. Appendix P provides evidence tables, summary risk of bias assessments, and assessments of strength of evidence for key comparisons and outcomes.

## Logic of Antidementia Drugs

The AChEIs (donepezil, galantamine, and rivastigmine) have consistently demonstrated a modest but positive benefit to cognition in persons with CATD from mild through severe stages. They may likewise provide benefit to persons with age-related cognitive decline or MCI through the same mechanisms of action by increasing the duration of action of acetylcholine in the synapse through inhibition of its breakdown by acetylcholinesterase. The drugs have been approved by the Federal Drug Administration for people with mild to moderate Alzheimer’s disease but not for people with age-related cognitive decline or MCI.

## Adults With Normal Cognition

We identified one study evaluating the use of antidementia medications versus placebo. The individual study results are presented in Table 4K.1. In this small (n=28) RCT of middle-aged menopausal women with subjective complaints of cognitive loss, donepezil had no effect on a variety of objective cognitive outcomes at 26 weeks.^263^ The study showed no cognitive benefits in people with normal cognition compared with placebo. No conclusion table is provided given evidence was insufficient due to limited data (single study with n<500).

Table 4K.1 Results overview: Antidementia medication in adults with normal cognition

Author Year Comparison N= Followup | Diagnosis | Biomarkers [specific biomarker] | Brief Cognitive Test Performance/Multidomain Neuropsychological Test Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
Donepezil Results Summary k=1; n=28 | NR | NR | NR | 0 of 2 (no difference) k=1 | 0 of 2 (no difference) k=1 | 0 of 4 (no difference) | NR
Devi, 2007^263^ Donepezil 5mg/d (6 weeks), then 10mg/d vs. placebo n=28 26 weeks | | | | NS [COWAT] | NS [WMS-III, Logical Memory] | 0 of 4 (no difference) | NR
Devi, 2007^263^ Donepezil 5mg/d (6 weeks), then 10mg/d vs. placebo n=28 26 weeks | | | | NS [WMS-III, Working Memory] | NS [Buschke, List Learning]

COWAT: Controlled Word Association Test; k=number of studies included; mg/d=milligrams per day; n=sample size; NR=not reported; NS=no statistically significant difference; vs.=versus; WMS=Wecshler Memory Scale.

Shading indicates summary rows and columns.

## Adults With MCI

We identified 11 eligible publications reporting eight unique studies of antidementia drug interventions versus placebo to prevent cognitive decline in adults with MCI.^203, 213, 264, 265, 267–273^ All but one study were assessed as high risk of bias and not used in our analysis.^264, 265, 267–270, 272, 273^ Appendix P provides evidence tables, summary risk of bias assessments, and assessments of strength of evidence for key comparisons and outcomes. Conclusions are summarized in Table 4K.2 and individual study results in Table 4K.3.

Table 4K.2 Conclusions: Antidementia medications in adults with MCI

Comparison | Outcome | Conclusion | Strength of Evidence (justification)
AChEI (donepezil) vs. placebo k=1 | Dementia | No statistically significant difference in dementia diagnoses with donepezil versus placebo (n=769; 3 years), although improvement was noted at 18 and 24 months. | Low (medium study limitation, imprecise, unknown consistency)
AChEI (donepezil) vs. placebo k=1 | MCI | No data available. | Insufficient (no data)
AChEI (donepezil) vs. placebo k=1 | Brief cognitive test performance | No statistically significant difference in brief cognitive test performance with donepezil versus placebo (n=769; 3 years). | Low (medium study limitation, imprecise, unknown consistency)
AChEI (donepezil) vs. placebo k=1 | Multidomain neuropsychological performance | No statistically significant difference in multidomain neuropsychological performance with donepezil versus placebo (n=769; 3 years). | Low (medium study limitation, imprecise, unknown consistency)
AChEI (donepezil) vs. placebo k=1 | Executive/Attention/Processing speed | No statistically significant difference in executive function/attention/processing speed with donepezil versus placebo (n=769; 3 years). | Low (medium study limitation, imprecise, unknown consistency)
AChEI (donepezil) vs. placebo k=1 | Memory | No statistically significant difference in memory with donepezil versus placebo (n=769; 3 years). | Low (medium study limitation, imprecise, unknown consistency)

AChEI=acetylcholinesterase inhibitor; k=number of studies included; MCI=mild cognitive impairment; n=sample size

Table 4K.3 Results Overview: Antidementia medications in adults with MCI

Author Year Comparison N=Follow-up | Diagnosis | Biomarkers [specific biomarker] | Brief Cognitive Test Performance/Multidomain Neuropsychological Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
Donepezil Results Summary k=1; n=769 | 0 of 1 (no difference) k=1 | 0 of 4 (no difference) k=1 | BCT 0 of 1 (no difference at 3 years) k=1 MNP 0 of 2 (no difference at 3 years) k=1 | 0 of 1 (no difference) k=1 | 0 of 1 (no difference) k=1 | 0 of 9 (no difference at 3 years)
Petersen, 2005 ^203^ Jack, 2008^213^ Donepezil 5mg/d (6 weeks), then 10mg/d vs. placebo n=769 3 years (MRI outcomes = High ROB)^213^ | I>C at 6 & 12 mo, then NS [Clinical Criteria] | | BCT I>C until 2 years, then NS [MMSE] | NS [Composite] | I>C at 6 and 18 mo, then NS [Composite] | 0 of 5 (no difference at 3 years) | NS [Mortality]
Petersen, 2005 ^203^ Jack, 2008^213^ Donepezil 5mg/d (6 weeks), then 10mg/d vs. placebo n=769 3 years (MRI outcomes = High ROB)^213^ | | | MNP NS [ADAS-Cog-Original]
Petersen, 2005 ^203^ Jack, 2008^213^ Donepezil 5mg/d (6 weeks), then 10mg/d vs. placebo n=769 3 years (MRI outcomes = High ROB)^213^ | | | MNP I>C until 18 mo, then NS [ADAS-Cog Modified]

ADAS-Cog=Alzheimer’s Disease Assessment Scale-Cognitive Subscale; BCT=brief cognitive test performance; C=control; I=intervention; k=number of studies included; mg/d=milligrams per day; MMSE=Mini-Mental State Examination; MNP=multidomain neuropsychological test performance; mo=month; MRI=magnetic resonance imaging; n=sample size; NS=no statistically significant difference; vs.=versus.

Shading indicates summary rows and columns.

One randomized controlled trial (RCT) (n=769) with medium risk of bias compared donepezil to placebo in adults with MCI.^203^ Petersen et al. found low-strength evidence that donepezil reduced the likelihood of progression to dementia at 1 year but not at 3 years.^203^

Petersen et al. also assessed cognition with a brief test of cognitive performance (Mini-Mental State Examination, MMSE), two tests of multidomain neuropsychological performance, one test of executive function/attention/processing speed, and a memory composite.^203^ Donepezil performed better than placebo on the MMSE for the first 2 years and on two cognitive test composites (one related to executive/attention/processing speed and the other related to memory) until 18 months, after which there were no differences between groups. No other differences between groups were observed. ApoE4 carriers on donepezil had a reduced likelihood of progression to dementia throughout the 3-year study.

## Interpreting the Findings

The single study with low to medium risk of bias that examined diagnostic outcomes suggests at most a modest benefit of an AChEI (donepezil) in delaying progression from MCI to CATD over 18 months to 2 years, but no benefit of AChEI versus placebo is seen at 3 years, which was the primary outcome. There are even fewer data available to assess the effects of AChEIs in persons with normal cognition; the strength of evidence was insufficient to conclude whether these drugs offer any benefits in this population.

Several large RCTs with high risk of bias were not used in this analysis, but came to the same conclusion: there was no significant benefit of antidementia drugs on the progression of MCI to CATD, biomarkers, or on overall cognitive function. After the earlier, 3-year trial of donepezil (which showed no effects after 3 years) had shown a positive effect at 1 year,^203^ donepezil was studied again in a 1-year RCT.^264^ Instead of conversion to CATD, the primary outcomes were the modified ADAS-Cog and CDR-sum of the boxes (CDR-SB). This dual primary efficacy endpoint was not reached, though a small but significant decrease (improvement) in the modified Alzheimer’s Disease Assessment Scale-Cognitive Subscale (ADAS-Cog) was seen. A 2-year RCT employing galantamine to prevent dementia^272, 273^ concluded that galantamine failed to significantly influence conversion to dementia. Similarly, a 2-year RCT examining the use of rivastigmine in people with MCI found no significant benefit on rate of progression to Alzheimer’s disease or on cognitive function over 4 years.^265^

Several high risk of bias studies examined biomarkers in people with MCI. A 2-year study of galantamine (n=364) found lower rates of brain atrophy in those taking galantamine, but no difference between galantamine and placebo groups in rate of hippocampal atrophy.^273,272^ Similarly, data collected as part of the 1-year trial of donepezil in MCI revealed no significant difference in the primary outcome of annualized percentage change (APC) in hippocampal volumes^264^ but a significant differences favoring drug (less volume loss) in the secondary outcome of APC in whole brain volumes.^271^ While hippocampal volume loss/atrophy is associated with MCI and progression to CATD, and whole brain atrophy is seen in Alzheimer’s disease, particularly in the later stages, the significance of these whole brain changes is not obvious, particularly given the negative clinical results of both trials. A number of reviews have looked at the effects of AChEIs on the progression from MCI to CADT. They used more studies than qualified for this review. Some have suggested modest initial benefit that was not sustained^274–276^. They also noted higher rates of adverse events.^275, 276^

* Note that the literature currently does not use the term CATD; we specified whenever the diagnosis of dementia was defined.