# 4J Results: Nonsteroidal Anti-Inflammatory Drugs

## Key Messages

- No evidence was available for the effect of low-dose aspirin on mild cognitive impairment (MCI) or clinical Alzheimer’s-type dementia (CATD)^*^ incidence.
- Low-strength evidence shows no benefit for low-dose aspirin on brief cognitive screening tests, multidomain neuropsychological performance, or memory, even with 10 years of use.
- Low-strength evidence shows no benefit for nonsteroidal anti-inflammatory drugs (NSAIDs), including both selective and nonselective cyclooxygenase-2 (COX-2) inhibitors, to reduce CATD incidence, or to benefit multidomain neuropsychological performance or memory, with 8 years of followup after 1 to 3 years of use.

## Eligible Studies

We identified eight eligible publications reporting four unique studies of NSAIDs to prevent age-related cognitive decline, MCI, or CATD.^255–261^ Two were assessed as high risk of bias and were not used in our analysis.^260, 261^ We separately analyzed the efficacy of NSAID interventions for adults with normal cognition and those with MCI. Appendix O provides evidence tables, summary risk of bias assessments, and assessments of strength of evidence for key comparisons and outcomes.

## Logic of NSAIDs

Numerous epidemiological studies have shown an association between NSAID use and a reduced prevalence of dementia, specifically Alzheimer’s disease.^262^ The brains of those with Alzheimer’s disease have abundant amyloid plaque, which is associated with an inflammatory reaction and related neurodegeneration. In vitro and animal models of Alzheimer’s disease pathology show that NSAIDs reduce plaque-related inflammation and improve function, both at a cellular and behavioral level.

## Adults With Normal Cognition

### NSAIDs Versus Placebo

Two randomized controlled trials (RCTs) in five publications with low to medium risk of bias enrolling a total of 8,905 adults compared NSAIDs to placebo in adults with normal cognition.^255–259^ Sample sizes were 2,528 and 6,377. The results of these studies are summarized in Tables 4J.1 and 4J.2.

Table 4J.1 Conclusions: NSAIDs in adults with normal cognition

Comparison | Outcome | Conclusion | Strength of Evidence (justification)
Aspirin vs. placebo k=1 | Dementia | No data available. | Insufficient (no data)
Aspirin vs. placebo k=1 | MCI | No data available. | Insufficient (no data)
Aspirin vs. placebo k=1 | Brief cognitive test performance | No benefit in brief cognitive test performance with aspirin versus placebo long term (n=6,377; 10 years). | Low (medium study limitations, indirect, unknown consistency)
Aspirin vs. placebo k=1 | Multidomain neuropsychological performance | No benefit in multidomain neuropsychological performance with aspirin versus placebo long term (n=6,377; 10 years). | Low (medium study limitations, indirect, unknown consistency)
Aspirin vs. placebo k=1 | Executive/Attention/Processing speed | No data available. | Insufficient (no data)
Aspirin vs. placebo k=1 | Memory | No benefit in memory with aspirin versus placebo long term (n=6,377; 10 years). | Low (medium study limitations, indirect, unknown consistency)
Non-aspirin NSAIDs vs. placebo k=1 | Dementia | No significant difference in dementia diagnosis with celecoxib/naproxen versus placebo (n=2,117; 8 years). | Low (medium study limitations, direct, unknown consistency)
Non-aspirin NSAIDs vs. placebo k=1 | MCI | No data available. | Insufficient (no data)
Non-aspirin NSAIDs vs. placebo k=1 | Brief cognitive test performance | No benefit in brief cognitive test performance with celecoxib/naproxen versus placebo long term (n=2,117; 8 years). | Low (medium study limitations, indirect, unknown consistency)
Non-aspirin NSAIDs vs. placebo k=1 | Multidomain neuropsychological performance | No benefit with celecoxib/naproxen versus placebo in multidomain neuropsychological performance long term (n=2,117; 8 years). | Low (medium study limitations, indirect, unknown consistency)
Non-aspirin NSAIDs vs. placebo k=1 | Executive/Attention/Processing speed | No benefit in executive/attention/processing speed with celecoxib/naproxen versus placebo in long term (n=2,117; 8 years). | Low (medium study limitations, indirect, imprecise)
Non-aspirin NSAIDs vs. placebo k=1 | Memory | No benefit in memory with celecoxib/naproxen versus placebo in long term (n=2,117; 8 years). | Low (medium study limitations, indirect, imprecise)

k=number of studies included; MCI=mild cognitive impairment; n=sample size; vs.=versus

Table 4J.2 Results overview: NSAIDs versus inactive comparisons in adults with normal cognition

Author Year Comparison N= Followup | Diagnosis | Brief Cognitive Test Performance/Multidomain Neuropsychological Test Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
Aspirin Results Summary k=1; n=6,377 | | BCT 0 of 1 (no difference) MNP 0 of 1 (no difference) | | 0 of 1 (no difference) | 0 of 3 (no difference)
Kang, 2007^259^ Aspirin vs. placebo n=6,377 10 years | | BCT NS [TICS] MNP NS [Composite^1^] | | NS [Composite^2^] | 0 of 3 (no difference) | NR
NSAIDs Results Summary k=1; n=2,117 | 0 of 2 (no difference) | BCT 0 of 2 (no difference) MNP 0 of 2 (no difference) | 0 of 4 (no difference) | 0 of 6 (no difference) | 0 of 14 (no difference)
ADAPT^255–258^ Celecoxib or naproxen vs. placebo n=2,117 8 years (diagnosis) 4 years (brief cognitive test performance, multidomain neuropsychological performance, executive/attention/processing speed, memory) | Celecoxib: NS Naproxen: NS [CATD] | BCT Celecoxib: NS Naproxen: NS [3MS] MNP Celecoxib: NS Naproxen: NS [Composite^3^] | Celecoxib: NS Naproxen: NS [DS Forward] Celecoxib: NS Naproxen: NS [DS Backward] | Celecoxib: NS Naproxen: NS [HVLT] Celecoxib: NS Naproxen: NS [RBMT] Celecoxib: NS Naproxen: NS [BVMT] | 0 of 14 (no difference) | Study discontinued due to increased cardiovascular risk from celecoxib

a TICS, category fluency, 10 words list (immediate and delayed recall),

b EBMT; 10 words list (immediate and delayed recall), EBMT;

c HVLT, informant-rated Dementia Severity Rating Scale, DS, Naming supermarkets, RBMT

3MS=Modified Mini-Mental State Examination; BCT=brief cognitive test performance; BVMT=Brief Visuospatial Memory Test; C=inactive control; CATD=Clinical Alzheimer’s Type Disease; DS=Digit Span (Forward and/or Backward); EBMT=East Boston Memory Test; HVLT=Hopkins Verbal Learning Test; k=number of studies included; I=intervention; MNP=multidomain neuropsychological test performance; n=sample size; NS=no statistically significant difference; NSAIDs=Nonsteroidal anti-inflammatory drugs; NR=not reported; RBMT=Rivermead Behavioral Memory Test; TICS=Telephone Interview for Cognitive Status; vs.=versus

Shading indicates summary rows and columns.

One trial (n=6,377) compared aspirin (100 mg every other day) to placebo.^259^ Subjects were drawn from a pool of 39,876 participants in the Women’s Health Study, which enrolled healthy women age 45 and over from 1992 to 1995. No cognitive assessment was performed at baseline. Participants were eligible for the cognitive substudy if they were aged 65 or more and completed an initial cognitive assessment by telephone an average of 5.6 years after randomization. The primary outcome was a global score averaging performance across a battery of cognitive tests in two followup assessment up to a mean of 4 years after the initial cognitive assessment (9.6 years after randomization). The key secondary outcome was a score averaging four measures of verbal memory. The sample provided at least 80 percent power to detect a modest relative risk of 0.76 in aspirin compared with placebo. The trial compared treatment groups in both mean cognitive scores at followup and in change from baseline for brief cognitive test performance, multidomain neuropsychological performance, and memory. The aspirin group performed significantly better in only one of four cognitive tests at only one of two followups, and no better than placebo in change from baseline for any cognitive performance test at the final followup.

The ADAPT trial (n=2,528) was specifically designed to test the hypothesis that NSAIDs, either selective (celecoxib) or nonselective (naproxen) cyclooxygenase-2 inhibitors, would work for the primary prevention of CATD.^255–258^ The trial had three arms comparing celecoxib (200 mg twice daily) or naproxen (220mg twice daily) with placebo. Subjects were men and women aged 70 or older with a family history (at least one first-degree relative) of CATD.

The ADAPT trial reported CATD diagnosis at 8-year followup, and brief cognitive test performance, multidomain neuropsychological performance, executive/attention/processing speed, and memory at 4-year followup. No benefit with either type of NSAID was found for any outcome.

## Adults With MCI

The only eligible study had a high risk of bias.^260^

## Interpreting the Findings

Despite the compelling epidemiological data and strong pathophysiological rationale, there is no evidence for whether NSAIDs prevent MCI or CATD, and limited available evidence shows no benefit of NSAIDs versus placebo for improving or slowing decline of cognitive performance in adults with normal cognition.

* Note that the literature currently does not use the term CATD; we specified whenever the diagnosis of dementia was defined.