# 4I Results: Lipid Lowering Treatment

## Key Messages

- Evidence was insufficient to assess the effect of 5 years of statin treatment on the risk of incident clinical Alzheimer’s-type dementia (CATD)^*^ or for preventing mild cognitive impairment (MCI).
- Low-strength evidence shows a small, 6-month improvement in executive/attention/processing speed with placebo treatment that was not found with statin treatment, presumed to be due to practice effects and of uncertain clinical significance.
- Low-strength evidence shows no benefit on brief cognitive test performance, executive/attention/processing speed, or memory for statin plus fenofibrate versus statin plus placebo in adults with normal cognition.
- Evidence was insufficient to assess whether effects of statins on any cognitive outcomes differ by patient age, baseline lipid level, or other characteristics.

## Eligible Studies

We identified 10 eligible publications reporting nine unique studies that compared treatment with lipid lowering medications versus control treatment to prevent age-related cognitive decline, MCI, or CATD.^193, 236, 243–250^ Three publications from two studies were rated high risk of bias and excluded from our analyses.^246, 249, 250^ The remaining seven studies with low to medium risk of bias were randomized controlled trials (RCTs) that enrolled a total of 23,286 adults.^193, 236, 243–245, 247, 248^ Appendix N provides evidence tables, summary risk of bias assessments, and assessments of strength of evidence for key comparisons and outcomes.

## Logic of Lipid Lowering Treatments

A systematic review of prospective cohort studies found mixed results regarding whether saturated fat intake was positively associated with CATD, MCI, or cognitive decline.^251^ Authors cited studies suggesting that intracellular cholesterol may impact brain beta amyloid production and deposition. In 2012, based largely on post-marketing adverse event reporting, the Federal Drug Administration revised labeling for statins to warn of a possible associated increase in risk of memory loss, forgetfulness and confusion. These effects were characterized as mild and reversed by stopping use of the statin.^252^ However, subsequent systematic reviews of RCTs in both individuals who were cognitively normal and those with CATD showed no difference between statins and placebo in cognitive test performance,^253^ including no protective effect with late-life statin use.^254^

## Adults With Normal Cognition

Only two studies excluded participants based on any cognitive criteria; one excluded individuals with a diagnosis of clinical dementia^236^ and another excluded individuals with a score on the Mini-Mental State Examination (MMSE) of <24.^247^ No studies reported information on the proportion of participants with any cognitive impairment or diagnosis at baseline. Given that, and the largely normal baseline cognitive test performance in the studies that reported results of baseline cognitive testing, participants in all eligible lipid lowering medication versus control trials were presumed to have normal cognition. A summary of conclusions is provided in Table 4I.1 and individual study results are in Table 4I.2.

Table 4I.1 Conclusions: Lipid lowering interventions in adults with normal cognition

Comparison | Outcome | Conclusion | Strength of Evidence (justification)
Statins vs. placebo k=4 | Dementia | Unable to draw conclusion. | Insufficient (medium study limitations, unknown precision, unknown consistency, suspected reporting bias)
Statins vs. placebo k=4 | MCI | No data available. | Insufficient (no data)
Statins vs. placebo k=4 | Brief cognitive test performance | Unable to draw conclusion. | Insufficient (medium study limitations, unknown precision, unknown consistency, suspected reporting bias)
Statins vs. placebo k=4 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
Statins vs. placebo k=4 | Executive/Attention/Processing speed | Statistically significant improvement in 2 of 3 executive/attention/process speed outcomes for placebo versus statins (n=948; 6 months). | Low (medium study limitations, imprecise, inconsistent)
Statins vs. placebo k=4 | Memory | Unable to draw conclusion. | Insufficient (medium study limitations, imprecise, inconsistent, suspected reporting bias)
Statin plus fenofibrate vs. statin plus placebo k=1 | Dementia | No data available. | Insufficient (no data)
Statin plus fenofibrate vs. statin plus placebo k=1 | MCI | No data available. | Insufficient (no data)
Statin plus fenofibrate vs. statin plus placebo k=1 | Brief cognitive test performance | No statistically significant difference in brief cognitive test performance with statins plus fenofibrate versus statins plus placebo (n=1,538; 40 months) | Low (low study limitations, unknown consistency, suspected reporting bias)
Statin plus fenofibrate vs. statin plus placebo k=1 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
Statin plus fenofibrate vs. statin plus placebo k=1 | Executive/Attention/Processing speed | No statistically significant difference in executive/attention/processing speed with statins plus fenofibrate versus statins plus placebo (n=1,538; 40 months). | Low (low study limitations, suspected reporting bias)
Statin plus fenofibrate vs. statin plus placebo k=1 | Memory | No statistically significant difference in memory with statins plus fenofibrate versus statins plus placebo (n=1,538; 40 months). | Low (low study limitations, unknown consistency, suspected reporting bias)

k=number of studies included; MCI=mild cognitive impairment; n=sample size; vs.=versus

Table 4I.2 Results overview: Lipid lowering interventions in adults with normal cognition

Author Year Comparison N= Followup | Diagnosis | Biomarkers [specific biomarker] | Brief Cognitive Test Performance/Multidomain Neuropsychological Test Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
Statin vs. Placebo Results Summary k=4; n=21,484 | 0 of 1 (no difference) k=1 | NR | BCT 0 of 2 (no difference) k=1 | 0 of 4 favored I 3 of 4 favored C k=2 | 0 of 4 favored I 1 of 4 favored C k=2 | 0 of 10 favored I 4 of 10 favored C | 0 of 3 (no difference) k=3
Muldoon, 2004^245^ Simvastatin 10 mg daily or Simvastatin 40 mg daily vs. placebo n=308 6 months | | | | C>I [Composite Executive/Attention/Processing Speed 1]^a^ | C>I [Memory Composite 1] | 0 of 3 favored I 2 of 3 favored C | 1 person with drew in active therapy due to stroke
Muldoon, 2004^245^ Simvastatin 10 mg daily or Simvastatin 40 mg daily vs. placebo n=308 6 months | | | | | NS [Memory Composite 2]
Heart Protection Study, 2002^243^ Simvastatin 40 mg daily vs. matching placebo n=20,536 5 years | NS [Reported number who developed dementia] | | BCT NS [TICS] | | | 0 of 2 (no difference) | NS [Hospitalizations]
Heart Protection Study, 2002^243^ Simvastatin 40 mg daily vs. matching placebo n=20,536 5 years | | | BCT NS [TICS <22]
Muldoon, 2000^244^ Lovastatin 20 mg daily vs. matching-placebo n=209 6 months | | | | C>I [Composite Measure of Attention]^b^ | NS [Working Memory Composite] | 0 of 4 favored I 2 of 4 favored C | NR
Muldoon, 2000^244^ Lovastatin 20 mg daily vs. matching-placebo n=209 6 months | | | | C>I [Composite Measure Psychomotor Speed] | NS [Memory Recall Composite]
Santanello, 1997^247^ lovastatin 20mg daily vs. lovastatin 40mg daily vs. placebo n=431 6 months | | | | NS [DSST] | | 0 of 1 (no difference) | NS [number of events reported]
Statin Plus Ezetimibe Versus Placebo Results Summary k=1; n=34 | | 1 of 5 favor I k=1 | BCT 0 of 1 (no difference) k=1 | 1 of 1 favor I k=1 | 1 of 2 favor I k=1 | 3 of 9 favor I
Tendolkar, 2012^248^ Atorvastatin 20mg for 2 weeks then increased to 40mg, after 4 weeks ezetimibe 10mg was added. Standard anticoagulant therapy vs. matching-placebo and standard anticoagulant therapy n=34 1 year | | I>C [Left Amygdala Volume] | BCT [MMSE]^c^ | I>C [DSST] | NS [Dutch Version RAVLT Immediate Word Recall] | 3 of 9 favor I | NR
| | NS [Right Amygdala Volume] | | | I>C [Dutch version RAVLT Delayed Word Recall]
| | NS [Left Hippocampal Volume]
| | NS [Right Hippocampal Volume]
| | NS [White Matter Lesion Volume]
Statin plus Fenofibrate versus Statin plus Placebo Results Summary k=1; n=1,538 | | | BCT 0 of 1 (no difference) k=1 | 0 of 2 (no difference) k=1 | 0 of 1 (no difference) k=1 | 0 of 4 (no difference)
Willamson, 2014^236^ (ACCORD-MIND Lipid trial) Statin plus Fenofibrate vs. statin n=1538 40 months | | | BCT NS [MMSE] | NS [SCWT] | NS [RAVLT] | 0 of 4 favored I | NR
Willamson, 2014^236^ (ACCORD-MIND Lipid trial) Statin plus Fenofibrate vs. statin n=1538 40 months | | | | NS [DSST]
Comparative Effectiveness k=2; n=230
Muldoon, 2004^245d^ Simvastatin 10mg daily vs. Simvastatin 40mg daily n=189 6 months | | | | | | | 1 person with drew in active therapy due to stroke
Carlsson, 2002^193^ Pravastatin 20mg daily vs. tocopherol 440 IU daily n=41 6 month followup | | | | NS [DSST] | | 0 of 1 (no difference) | NS [Physical adverse events and hospitalizations]

a Muldoon 2004^245^ evaluated composite measures. If the composite measure was significant then individual measures within the composite were tested. The test of the composite measures within the composite executive/attention/processing speed 1: NS [Digit Vigilance], C>I [Recurrent Words], C>I [Elithorn Mazes]. The test of the composite measures within memory composite: NS [Mirror Tracking], C>I [4-Word Memory]

b Muldoon 2000^244^ evaluated composite measures. If the composite measure was significant then individual measures within the composite were tested. The test of the composite measures within the attention composite: C>I [Digit Vigilance], C>I [Recurrent Words], C>I [Elithorn Maze]

c Tendolkar 2012^248^ did not report between-group difference at followup.

d Muldoon 2004^245^ compared simvastatin 10 mg versus simvastatin 40 mg. Not enough information was reported in the text to extract data. The authors comment on the comparison: “when the two active treatment groups (10 mg and 40 mg) were compared to test for the presence of a dose response relation, we found that the 40 mg dose of simvastatin did not have greater effects on cognitive performance than the 10 mg dose (P >0.15)”

BCT=brief cognitive test performance; C=control; DSST=Digit Symbol Substitution Test; I=intervention; k=number of studies included; mg=milligrams; MMSE=Mini-Mental State Examination; n=sample size; NR=not reported; NS=no statistically significant difference; RAVLT=Rey Auditory Verbal Learning Test; SCWT=Stroop Color Word Test; TICS=Telephone Interview for Cognitive Status; vs.=versus

Shading indicates summary rows and columns.

### Statin Versus Placebo

Four low to medium risk of bias RCTs randomized participants to statin versus placebo and reported cognitive outcomes (n=21,484).^243–245, 247^ One large study randomized 20,536 participants to simvastatin (40 mg/day) versus placebo and followed them for 5 years. One trial randomized 209 participants to lovastatin (20 mg/day) versus placebo,^244^ and another randomized 308 participants to simvastatin (10 or 40 mg/day) versus placebo and followed them for 6 months. A fourth study randomized 431 participants to lovastatin (20 or 40 mg/day) versus placebo, respectively, and followed them for 6 months.^247^ Three studies assessed baseline cognition and found at least normal functioning.^244, 245, 247^ One study reported no information about baseline cognitive function.^243^ Mean baseline age ranged between 46 and 71 years in three studies reporting, while age range was 40–80 years in a fourth study.

Only one study, which was not originally designed to evaluate cognitive outcomes, reported data on incident MCI or CATD. It reported no difference in the risk of incident dementia during 5 years of followup between participants assigned to statin versus placebo.^243^ The same study found no difference between treatment groups in brief cognitive screening test performance at 5 years. However, the strength of evidence was insufficient.

One trial, which compared 40 mg/day lovastatin, 20 mg/day lovastatin, and placebo groups, found no between-treatment difference in change from baseline in one test of executive/attention/processing speed.^247^ Two other trials by the same investigators reported between-group differences favoring the placebo group for executive/attention/processing speed, but not for memory. Participants assigned to the placebo group experienced small improvements in performance across all tested cognitive domains at 6 months versus baseline that was thought to be attributable to practice effects, while participants in the statin group had similar improvements from baseline only in memory, but no change from baseline in other cognitive domains. Low-strength evidence from these three studies suggested that statins are associated with less improvement at 6 months than placebo in the domains of executive/attention/processing speed (effect sizes for between-treatment differences <0.2).^244, 245^ Evidence was insufficient for no difference between treatment groups in memory at 6 months.

None of these studies reported biomarker results.

One trial reported that between treatment effects on cognitive outcomes did not differ by age category (data not shown),^247^ and another reported that within the statin group a decline in cognition was only observed in those whose final low density lipoprotein (LDL) was below the study median,^244^ while the other two trials reported no subgroup results.

One study reported no difference between treatment groups in either the number of participants hospitalized (no data provided) or in the percentage of participants who discontinued treatment due to adverse events.^243^ Another reported more abdominal complaints in the two lovastatin groups compared to placebo, but no between-group differences in the proportion of participants with other adverse events.^247^ None of the other eligible studies reported adverse events data.

### Statin Plus Ezetimibe Versus Placebo

One RCT randomized 34 participants to atorvastatin 40 mg/day plus ezetimibe 10mg/day versus placebo and followed them for one year.^248^ Participants were excluded for a history of stroke or other severe neurologic condition. Mean baseline MMSE was 27.4 and mean NART IQ was 101.

No data on MCI or CATD outcomes were reported. All between-group differences in executive/attention/processing speed and memory were small and unlikely to be clinically meaningful. Compared with the placebo group, participants randomized to atorvastatin plus ezetimibe had statistically significantly less decline in left amygdala volume, but not in decline in right amygdala volume, in decline in right or left hippocampal volume, or in change in white matter lesion volume.^248^ The study did not report any subgroup analyses for cognitive outcomes. This study reported no data on adverse events outcomes.

### Statin Plus Fenofibrate Versus Statin Plus Placebo

One study met eligibility criteria with low risk of bias and randomized a subset of participants in the ACCORD trial (n = 10,251 with diabetes and high risk for cardiovascular events).^236^ Individuals were excluded from participation if they had preexisting clinical evidence of dementia. Other than reporting a median baseline MMSE of 28, baseline cognitive status was not further defined.

This study reported no data on MCI or CATD outcomes. The study provided low-strength evidence that treatment with statin plus fenofibrate is similar to treatment with statin plus placebo for brief cognitive test performance (MMSE), two measures of executive/attention/processing speed, and memory at 40-month followup. There were no consistent between-treatment differences in change in cognitive performance from baseline as a function of baseline age, gender, executive/attention/processing speed, history of cardiovascular disease, or diabetes duration. The study reported no data on adverse events.

### Statin Versus Alpha Tocopherol

One trial met eligibility criteria with medium risk of bias and randomized 41 older adults with high LDL levels to pravastatin 20 mg/day versus tocopherol 400 IU/day for 6 months.^193^ The study used no cognitive-related eligibility criteria.

The study reported no data on MCI or CATD outcomes. Although no significant change was observed in executive function within either treatment group between baseline and 6 months, results of direct between-group comparisons were not reported. The study reported no data on biomarkers relevant to cognitive function, and no subgroup analyses for cognitive outcomes. The study reported that there was no between-treatment group difference in any of an extensive list of physical adverse events (e.g., rash, diarrhea, dizziness).

## Adults With MCI

None of the studies were restricted to participants with MCI and none reported results for individuals with MCI.

## Interpreting the Findings

Among included studies, statins did not show evidence of improving or maintaining cognitive function versus placebo. Further, though of uncertain clinical significance, in two 6-month studies small improvements versus baseline in nonmemory domains from presumed practice effects were only observed in the placebo and not the statin group. The only study that reported any outcomes favoring intervention compared statin plus ezetimibe versus placebo in only 34 participants, and reported additional results showing no treatment group difference in cognitive performance. Studies were limited by followup that likely was too short to observe clinically meaningful changes in cognition in the middle-aged and older and largely cognitively normal participants.

* Note that the literature currently does not use the term CATD; we specified whenever the diagnosis of dementia was defined.