# 4H Results: Antihypertensive Treatment

## Key Messages

- Generally, low-strength evidence shows that 3 to 4.7 years of antihypertensive treatment regimens versus placebo appear to have no benefit on cognitive test performance in adults with normal cognition.
- Moderate-strength evidence shows that angiotensin converting enzyme (ACE) plus thiazide versus placebo and angiotensin receptor blockers (ARBs) versus placebo have no benefit on brief cognitive screening tests.
- Low-strength evidence shows that intensive versus standard antihypertensive control shows no benefit on cognitive test performance.
- Low-strength evidence shows no benefit on cognitive test performance of any fixed antihypertensive treatment regimen versus another among those directly compared.
- Effects of stepped multiple agent antihypertensive medication regimens to reduce risk of dementia are inconsistent; one trial showed a positive effect but three other trials found no effect of antihypertensive treatment on clinical Alzheimer’s-type dementia (CATD)^*^ incidence.
- The only two trials that reported subgroup data found no differential effect of treatment group on cognition by participant age or other baseline characteristics.

## Eligible Studies

We identified 20 eligible publications reporting 16 unique trials comparing antihypertensive medication treatment to placebo or active control to prevent age-related cognitive decline, mild cognitive decline (MCI), or CATD.^218–241^ Three trials were assessed as high risk of bias and not used in our analysis.^219, 225, 229^ We did not include studies specifically designed to address clear post-stroke dementia, however, studies addressing mixed dementias including a vascular component were included. For our analyses, we evaluated the efficacy and comparative effectiveness of antihypertensive treatment regimens and the strength of evidence for these effects by drug class, but in the text below we present the results within the broader groups of antihypertensive medication treatment (single or multiple agents) versus placebo, intensive versus standard antihypertensive treatment (with respect to blood pressure treatment targets), and antihypertensive medication treatments versus each other (either or both treatment groups may be single or multiple agents). We also evaluated and report results separately for adults with normal cognition and those with MCI. Appendix M provides evidence tables, summary risk of bias assessments, and assessments of strength of evidence for key comparisons and outcomes.

## Logic of Antihypertensive Treatments

A meta-analysis of prospective cohort studies estimated that the presence of hypertension between the ages of 35 and 64 years but not in late life increased the risk of incident Alzheimer’s disease by more than 50 percent.^242^ Hypertension is thought to contribute to risk of both vascular and Alzheimer’s dementia through unclear vascular mechanisms. Presumably hypertension is the cause or result of vascular changes in the blood supply to the brain that can adversely affect its function. It remains unclear whether this is a direct effect or the result of other factors that affect both the vasculature and the brain.

## Adults With Normal Cognition

Conclusions are summarized in Table 4H.1 and individual study results in Table 4H.2.

Table 4H.1 Conclusions: Antihypertensives in adults with normal cognition

Comparison | Outcome | Conclusion | Strength of Evidence (justification)
Antihypertensive(s) vs. placebo
ARBs vs. placebo k=3 | Dementia | No statistically significant difference in dementia diagnoses with ARBs versus placebo (n=4,937; 44 months). | Low (medium study limitations, unknown consistency, suspected reporting bias)
ARBs vs. placebo k=3 | MCI | No data available. | Insufficient (no data)
ARBs vs. placebo k=3 | Brief cognitive test performance | No statistically significant difference in brief cognitive test performance with ARBs versus placebo (n=10,863; up to 56 months). | Moderate (medium study limitations, suspected reporting bias
ARBs vs. placebo k=3 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
ARBs vs. placebo k=3 | Executive/Attention/Processing speed | Unable to draw conclusion. | Insufficient (medium study limitations, unknown consistency, suspected reporting bias)
ARBs vs. placebo k=3 | Memory | Unable to draw conclusion. | Insufficient (medium study limitations, inconsistent, suspect reporting bias)
Beta blocker vs. placebo k=1 | Dementia | No data available. | Insufficient (no data)
Beta blocker vs. placebo k=1 | MCI | No data available. | Insufficient (no data)
Beta blocker vs. placebo k=1 | Brief cognitive test performance | No data available. | Insufficient (no data)
Beta blocker vs. placebo k=1 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
Beta blocker vs. placebo k=1 | Executive/Attention/Processing speed | Unable to draw conclusion. | Insufficient (medium study limitations, unknown precision, unknown consistency, suspected reporting bias)
Beta blocker vs. placebo k=1 | Memory | Unable to draw conclusion. | Insufficient (medium study limitations, unknown precision, unknown consistency, suspected reporting bias)
ACE and Thiazide vs. placebo k=2 | Dementia | No statistically significant difference in dementia diagnoses with ACE and thiazide versus placebo (n=14,985; up to 4.3 years) | Low (medium study limitations, imprecise suspected reporting bias)
ACE and Thiazide vs. placebo k=2 | MCI | No data available. | Insufficient (no data)
ACE and Thiazide vs. placebo k=2 | Brief cognitive test performance | No statistically significant difference in brief cognitive test performance with ACE and thiazide versus placebo (n=14,985; up to 4.3 years) | Moderate (medium study limitations, suspected reporting bias)
ACE and Thiazide vs. placebo k=2 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
ACE and Thiazide vs. placebo k=2 | Executive/Attention/Processing speed | No data available. | Insufficient (no data)
ACE and Thiazide vs. placebo k=2 | Memory | No data available. | Insufficient (no data)
Combination therapy vs. placebo k=3 | Dementia | Statistically significant difference in dementia diagnoses favoring combination therapy versus placebo (n=3,228; up to 3.9 years). | Low (medium study limitations, imprecise, unknown consistency, suspected reporting bias)
Combination therapy vs. placebo k=3 | MCI | No data available | Insufficient (no data)
Combination therapy vs. placebo k=3 | Brief cognitive test performance | No statistically significant difference in brief cognitive test performance with beta blocker versus placebo (n=3,228; up to 3.9 years). | Low (medium study limitations, suspected reporting bias)
Combination therapy vs. placebo k=3 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
Combination therapy vs. placebo k=3 | Executive/Attention/Processing speed | Unable to draw conclusion. | Insufficient (medium study limitations, unknown precision, unknown consistency, suspected reporting bias)
Combination therapy vs. placebo k=3 | Memory | No data available. | Insufficient (no data)
Intensive vs. Standard
Intensive blood pressure control (systolic blood pressure <120 mmHg) vs. standard blood pressure control (standard therapy (systolic blood pressure <140 mmHg) k=1 | Dementia | No data available. | Insufficient (no data)
Intensive blood pressure control (systolic blood pressure <120 mmHg) vs. standard blood pressure control (standard therapy (systolic blood pressure <140 mmHg) k=1 | Brief cognitive test performance | Unable to draw conclusion. | Insufficient (medium study limitations, unknown consistency, suspected reporting bias)
Intensive blood pressure control (systolic blood pressure <120 mmHg) vs. standard blood pressure control (standard therapy (systolic blood pressure <140 mmHg) k=1 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
Intensive blood pressure control (systolic blood pressure <120 mmHg) vs. standard blood pressure control (standard therapy (systolic blood pressure <140 mmHg) k=1 | Executive/Attention/Processing speed | No statistically significant difference in executive/attention/processing speed with intensive blood pressure control versus standard blood pressure control (n=1,439; 40 months). | Low (medium study limitations, imprecise, suspected reporting bias)
Intensive blood pressure control (systolic blood pressure <120 mmHg) vs. standard blood pressure control (standard therapy (systolic blood pressure <140 mmHg) k=1 | Memory | No statistically significant difference in memory with intensive blood pressure control versus standard blood pressure control (n=1,439; 40 months). | Low (medium study limitations, unknown consistency, suspected reporting bias).
Antihypertensive vs. Antihypertensive
Ramipril (I1) up to 10 mg daily vs. (I2) combined ramipril up to 10 mg daily plus telmisartan 80mg daily k=1 | Dementia | No data available. | Insufficient (no data)
Ramipril (I1) up to 10 mg daily vs. (I2) combined ramipril up to 10 mg daily plus telmisartan 80mg daily k=1 | MCI | No data available. | Insufficient (no data)
Ramipril (I1) up to 10 mg daily vs. (I2) combined ramipril up to 10 mg daily plus telmisartan 80mg daily k=1 | Brief cognitive test performance | No statistically significant difference in brief cognitive test performance with ramipril versus ramipril combined with telmisartan (n=17,078; 56 months). | Low (medium study limitations, unknown consistency, suspected reporting bias)
Ramipril (I1) up to 10 mg daily vs. (I2) combined ramipril up to 10 mg daily plus telmisartan 80mg daily k=1 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
Ramipril (I1) up to 10 mg daily vs. (I2) combined ramipril up to 10 mg daily plus telmisartan 80mg daily k=1 | Executive/Attention/Processing speed | No data available. | Insufficient (no data)
Ramipril (I1) up to 10 mg daily vs. (I2) combined ramipril up to 10 mg daily plus telmisartan 80mg daily k=1 | Memory | No data available. | Insufficient (no data)
ARB vs. ACE k=3 | Dementia | No data available. | Insufficient (no data)
ARB vs. ACE k=3 | MCI | No data available. | Insufficient (no data)
ARB vs. ACE k=3 | Brief cognitive test performance | No statistically significant difference in brief cognitive test performance with ARB versus ACE (n=17,118; 56 months). | Low (medium study limitations, unknown consistency, suspected reporting bias)
ARB vs. ACE k=3 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
ARB vs. ACE k=3 | Executive/Attention/Processing speed | Unable to draw conclusion. | Insufficient (low study limitations, imprecise, unknown consistency, suspected reporting bias)
ARB vs. ACE k=3 | Memory | Unable to draw conclusion. | Insufficient (low study limitations, imprecise, inconsistent, suspected reporting bias)

ACE=angiotensin converting enzyme inhibitors; ARB=angiotensin receptor blocker; I1=intervention 1; I2=intervention 2; k=number of studies included; MCI=mild cognitive impairment; mg=milligram; mmHg=millimeter of mercury;

Table 4H.2 Results overview: Antihypertensive treatments in adults with normal cognition

Author Year Comparison N= Follow-up | Diagnosis | Biomarkers [specific biomarker] | Brief Cognitive Test Performance/Multidomain Neuropsychological Test Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
ARB vs. placebo Results Summary k=3; n=11,120 | 0 of 1 (no difference) k=1 | | BCT 0 of 4 (no difference) k=3 | 1 of 3 favored I k=1 | 1 of 2 favored I k=1 | 1 of 9 favored I | 0 of 1 (no difference) k=1
Anderson, 2011^218^ (TRANSCEND trial) telmisartan 80 mg daily vs. placebo n=5,926 56 months median followup | | | BCT NS [Drop of 3 or more MMSE points] | | | 0 of 1 (no difference) | NR
Saxby, 2008^231^ (single center in SCOPE trial) candesartan (8 mg – 16mg) daily vs. placebo n=257 44 months mean followup | | | BCT NS [MMSE] | NS [Executive Function Composite]^a^ | I>C [Episodic Memory Composite]^a^ | 2 of 6 favored I | NR
Saxby, 2008^231^ (single center in SCOPE trial) candesartan (8 mg – 16mg) daily vs. placebo n=257 44 months mean followup | | | | I>C [Attention Composite]^a^ | NS [Working Memory Composite]^a^
Saxby, 2008^231^ (single center in SCOPE trial) candesartan (8 mg – 16mg) daily vs. placebo n=257 44 months mean followup | | | | NS [Speed of Cognition Composite]^a^
Lithell, 2003^228^ Skoog 2005 ^232^ (SCOPE trial) Candesartan (8 mg – 16 mg) daily with hydrochlorothiazide 12.5 mg added as needed. When target blood pressure not achieved (<160/90 mmHg) other drugs added as needed vs. placebo daily and hydrochlorothiazide 12.5 mg added as needed. When target blood pressure not achieved (<160/90 mmHg) other drugs added as needed n=4,937 44 months mean followup | NS [Dementia] | | BCT NS [MMSE] | | | 0 of 2 (no difference)
| | | NS [Significant Cognitive Decline] | | | | NS [serious adverse events]
Beta Blocker Results Summary k=1; n=2,401 | | | | 0 of 1 (no difference) | 0 of 1 (no difference) | 0 of 2 (no difference)
Bird, 1990 ^220^ atenolol 50 mg daily vs. placebo n=2,401 9 months | | | | NS [TMT A] | NS [PAL] | 0 of 2 (no difference) | NR
Combination Therapy Results Summary k=3; n=6,941 | 2 of 2 favors I k=2 | | BCT 0 of 2 (no difference) k=2 | 1 of 3 favors I k=1 | | 1 of 5 favors I
Forette, 2002 ^223^ (Syst-Eur trial) Antihypertensive stepwise therapy with titration with goal of lowering systolic blood pressure below 150 mmHg (step 1: nitrendipine 10–40 mg daily; step 2: enalapril 5 – 20 mg daily; step 3: hydrochlorothiazide 12.5 – 25 mg daily) vs. placebo n=3,228 3.9 years median follow up | I>C [Dementia] | | BCT NS [MMSE] | | | 0 of 1 (no difference) | NR
Forette, 1998^224^ (Syst-Eur trial) Antihypertensive stepwise therapy with titration with goal of lowering systolic blood pressure below 150 mm Hg (step 1: nitrendipine 10 −40 mg daily; step 2: enalapril 5 – 20 mg daily; step 3: hydrochlorothiazide 12.5 – 25 mg daily) vs. placebo n=3,162 2-year median follow up | I>C [Dementia] | | BCT NS [MMSE] | | | 0 of 1 (no difference) | NR
Gurland, 1988^226^ (SHEP trial) Step therapy: step 1: chlorthalidone; step 2: reserpine, metoprolol, or hydralazine) vs. placebo n=551 1 year | | | | NS [DSST] | | 1 of 3 favors I | NR
Gurland, 1988^226^ (SHEP trial) Step therapy: step 1: chlorthalidone; step 2: reserpine, metoprolol, or hydralazine) vs. placebo n=551 1 year | | | | I>C [TMT A]
Gurland, 1988^226^ (SHEP trial) Step therapy: step 1: chlorthalidone; step 2: reserpine, metoprolol, or hydralazine) vs. placebo n=551 1 year | | | | NS [Composite]^b^
ACE and Thiazide vs. placebo Results Summary k=2; n=14,985 | 0 of 2 (no difference) k=2 | | BCT 0 of 3 (no difference) k=2 | | | 0 of 3 (no difference) | 1 of 2 favored I k=2
ACE and Thiazide vs. placebo
Peters, 2008^240^ (HYVET-COG) Indapamide 1.5 mg with optional perindopril (2 mg up to 4mg) vs. matching placebo n=3,845 26.4 months mean followup | NS | | BCT NS [MMSE] | | | 0 of 2 (no difference)
Peters, 2008^240^ (HYVET-COG) Indapamide 1.5 mg with optional perindopril (2 mg up to 4mg) vs. matching placebo n=3,845 26.4 months mean followup | | | NS [MMSE <24 or a decline of >3 MMSE points in a year] | | | | I>C [number of adverse events]
ADVANCE Collaborative Group, 2007^239^ Combined perindopril (2 mg up to 4 mg) and indapamide (0.625 mg up to 1.25 mg) and open label perindopril up to 4 mg vs. matching-placebo and open label perindopril up to 4 mg n=11,140 51 months mean followup | NS | | BCT NS [MMSE] | | | 0 of 1 (no difference) | NS [number with serious drug reactions]
Comparative Effectiveness: ARB versus ACE Results Summary k=3; n=17,331 | | | BCT 0 of 1 (no difference) k=1 | 0 of 1 (no difference) k=1 | 0 of 3 favored ARB 1 of 3 favored ACE | 0 of 5 favored ARB 1 of 5 favored ACE | 0 of 2 (no difference)
Hajjar, 2013 ^227^ Lisinopril (10 mg - 40 mg) vs. candesartan (8 mg – 32 mg) vs. hydrocholorothiazide (12.5 mg – 25 mg) n=53 6 months | | | | | | | NS
Andrerson, 2011^218^ (ONTARGET trial) ramipril (I_1_) 5 mg (increased to 10 mg after 2 weeks) daily vs. telmisartan (I_2_) 80mg daily n = 17,118 56 months median follow up | | | BCT NS [Drop of 3 or more MMSE points] | | | 0 of 1 (no difference) | NR
Forgari, 2006^222^ telmisartan 80mg and hydrochlorothiazide 12.5 mg daily (I_1_) vs. lisinopril 20 mg and hydrochlorothiazide 12.5 mg daily (I_2_) n=160 6 months | | | | NS [TMT B] | NS [Word List Memory] | 1 of 4 favored ACE | NS
Forgari, 2006^222^ telmisartan 80mg and hydrochlorothiazide 12.5 mg daily (I_1_) vs. lisinopril 20 mg and hydrochlorothiazide 12.5 mg daily (I_2_) n=160 6 months | | | | | I_1_>I_2_ [Word List Recall]
Forgari, 2006^222^ telmisartan 80mg and hydrochlorothiazide 12.5 mg daily (I_1_) vs. lisinopril 20 mg and hydrochlorothiazide 12.5 mg daily (I_2_) n=160 6 months | | | | | NS [Word List Recognition]
ARB vs. Thiazide Results Summary k=2; n=122 | | | | | | | 0 of 2 (no difference) k=2
Hajjar, 2013^227^ Lisinopril (10 mg - 40 mg) vs. candesartan (8 mg – 32 mg) vs. hydrocholorothiazide (12.5 mg – 25 mg) n=53 6 months | | | | | | | NS
Tedesco, 1999^235^ Losartan (I_1_) 50 mg daily vs. hydrochlorothiazide (I_2_) 25 mg daily n=69 26 months | | | | | | | NS
Comparative Effectiveness: Intensive vs. Standard Results Summary k=1; n=1,439 | NR | NR | BCT 0 of 1 (no difference) k=1 | 0 of 2 (no difference) k=1 | 0 of 1 (no difference) k=1 | 0 of 4 (no difference) | NR
Willamson, 2014^236^ (ACCORD BP trial) intensive intervention (systolic blood pressure <120 mmHg) vs. standard therapy (systolic blood pressure <140 mmHg) n=1,439 40 months | | | BCT NS [MMSE] | NS [SCWT] | NS [RAVLT] | 0 of 4 (no difference) | NR
Willamson, 2014^236^ (ACCORD BP trial) intensive intervention (systolic blood pressure <120 mmHg) vs. standard therapy (systolic blood pressure <140 mmHg) n=1,439 40 months | | | | NS [DSST]
Comparative Effectives: Intensive vs. standard
Antihypertensives versus Active Comparison Results Summary k=6; n=20,162
Hajjar, 2013^227^ Lisinopril (10 mg - 40 mg) vs. candesartan (8 mg – 32 mg) vs. hydrocholorothiazide (12.5 mg – 25 mg) n=53 6 months | | | | | | | NS
Sato, 2013^230^ (CAMUI trial) combined losartan 50 mg and hydrochlorothiazide 12.5 mg daily vs. combined amlodipine 5 mg and typical dosage of a angiotensin receptor blocker daily n=142 1 year | | | BCT NS [MMSE] | | | 0 of 1 (no difference) | NS
Anderson, 2011^218^ (ONTARGET trial) (I_1_) ramipril up to 10 mg daily vs. (I_2_) combined ramipril up to 10 mg daily plus telmisartan 80 mg daily n=17,078 56 months median follow up | | | BCT NS [Drop of 3 or more MMSE points] | | | 0 of 1 (no difference) | NR
Fogari, 2003^221^ Atenolol (I_1_ 50 mg with titration to 100 mg) vs. losartan (I_2_ 50 mg with titration to 100 mg) n=120 6 months | | | | | I_2_ > I_1_ [Word List Memory] | 2 of 2 favors I_2_ | NS
Fogari, 2003^221^ Atenolol (I_1_ 50 mg with titration to 100 mg) vs. losartan (I_2_ 50 mg with titration to 100 mg) n=120 6 months | | | | | I_2_ > I_1_ [Word List Recall]
Yodfat, 1996^237^ (LOMIR-MCT-IL trial) Isradipine (I_1_) 1.25 mg twice a day vs. methyldopa (I_2_) 250 mg twice a day vs. placebo (I_3_) n=368 12 months | | | | | | | NS [Life threatening events] I_2_ < I_1_, I_3_ [adverse reaction]
Bird, 1990^220^ atenolol 50 mg daily vs. moduretic (hydrochlorothiaz ide 25 mg and amiloride 2.5 mg) daily n=2,401 9 months | | | | NS [TMT A] | NS [PAL] | 0 of 2 (no difference) | NR

a Saxby 2008^231^ evaluated composite measures of episodic memory (composed of immediate word recall, immediate word recognition, delayed word recall, delayed word recognition, picture recognition), attention (composited simple reaction time, number vigilance, choice reaction time), working memory (composted of spatial memory, numeric working memory), speed of cognition (composed of reaction time scores from episodic memory recognition tasks, attention, and working memory tasks), and executive function (composed of TMT A & B, verbal fluency for letters F, A, and S, verbal fluency for category animals).

b Gurland 1988^226^ evaluated a composite executive/attention/processing speed measure composed of SHORT-CARE dementia, TMT, and DSST.

ACE=angiotensin converting enzyme inhibitors; ARB=angiotensin receptor blocker; BCT=brief cognitive test performance; C=control; DSST=Digit Symbol Substitution Test; I_1_=intervention 1; I_2_=intervention 2; k=number of studies included; MCI=mild cognitive impairment; mg=milligram; mmHg=millimeter of mercury; MMSE=Mini-Mental Status Examination; NS=no statistically significant difference; NR=not reported; PAL=Paired Association Learning Test; RAVLT=Rey Auditory Verbal Learning Test; SCWT=Stroop Color Word Test; TMT=Trail Making Test (Parts A & B) Shading indicates summary rows and columns.

### Antihypertensive Medication(s) Versus Placebo

Eight unique RCTs met eligibility criteria with low to medium risk of bias and randomized participants to an antihypertensive medication treatment (single or multiple agent) versus placebo,^218, 220, 223, 224, 226, 228, 231, 232, 237, 239–241^ Five of the eight studies had eligibility criteria related to cognition, including exclusion of participants with dementia;^223, 224, 226, 240^ any mental disorder or clinically relevant chronic disease;^237^ and either Mini-Mental State Examination (MMSE) <24, severe brain disorders that may interfere with cognitive function, or treatment with antidementia drugs.^228^ Four studies reported baseline MMSE, ranging from a median of 26 to 29.^218, 223, 224, 228, 240^

Among the four unique trials that reported incident dementia outcomes,^223, 224, 228, 239, 240^ only the Syst-Eur trial reported a significantly reduced risk of dementia in the antihypertensive treatment group versus the placebo group,^223, 224^ while the other three trials reported no difference in risk.^228, 239, 240^ During the double-blinded portion of the Syst-Eur trial, which was stopped early after planned interim analyses showed a significant reduction in stroke, 11 cases of incident dementia occurred in the antihypertensive treatment group (none with vascular dementia) and 21 in placebo group (two with vascular dementia). Intervention reduced the rate of incident dementia from 7.7 to 3.8 cases per 1000 patient-years (relative risk (RR) 0.50 [0.24–1.00]).

The Syst-Eur trial compared a stepped multiple agent antihypertensive regimen versus placebo, and defined incident dementia diagnosis based on Diagnostic Statistical Manual of Mental Disorders Third Edition (DSM-3) criteria and was validated by a masked review board.^170,171^ By comparison, among the three studies that showed no benefit on risk of CATD, one compared a stepped multiple agent antihypertensive regimen versus placebo,^240^ one compared a fixed antihypertensive agent combination versus placebo,^239^ and one compared monotherapy versus placebo.^228^ Among these three studies, a committee defined participants with incident dementia by consensus using DSM-4 criteria in one study,^240^ incident dementia was defined using modified ICD-10 research criteria in another,^228^ and no definitions were reported in the third study.^239^ Followup duration ranged between 2.2 and 4.3 years.

No study reported data on risk of incident MCI.

All eight trials reported at least one cognitive performance outcome.^218, 220, 223, 224, 226, 228, 231, 232, 237, 239, 240^ Four trials reported no difference in brief cognitive test performance between the antihypertensive medication treatment and placebo groups.

Three studies reported mixed results for a change in an executive/attention/processing speed test.^220, 226, 228, 231, 232^ All three trials reported results for attention; two trials found that individuals randomized to antihypertensive medication had significantly better attention than those assigned placebo,^228,226^ while the third study found no difference between treatment groups.^220^

Two studies reported results for a change in memory tests with mixed findings.^220, 231^ One study found no between-group difference in scores on the Paired Association Learning Test (PALS) after 9 months follow-up.^220^ In another, the antihypertensive treatment group had a statistically significantly smaller decline between baseline and 3.7 years follow-up in the episodic memory domain that was small in magnitude (Cohen D 0.28), but no difference in the change in working memory.^231^

None of these studies reported data on biomarkers.

Three of these eight studies reported information on adverse effects.^228, 237, 240^ Participants assigned to methyldopa, but not those assigned to calcium channel blocker, appeared significantly more likely than those assigned to a placebo to experience any adverse event, a sleep disorder, or a sexual disorder, while incidence of life-threatening events, and of headache, fatigue, and cardiovascular or gastrointestinal side effects were similar between each of these antihypertensive treatment groups and placebo.^237^ In one trial, significantly fewer serious adverse events occurred in the treatment group (p<0.01).^240^

The TRANSCEND study (ARB vs. placebo) was the only one of the eight eligible RCTs comparing antihypertensive medication treatment versus placebo that reported subgroup analyses.^218^ Authors reported no significant differential effects of treatment on cognitive outcomes in patient subgroups defined by age, history of hypertension, or previous stroke or transient ischemic attack (TIA), though they presented no data for these analyses.

### Intensive Versus Standard Antihypertensive Medication

Only one study with low to moderate risk of bias randomized 2,977 participants to intensive versus standard blood pressure control (goal systolic blood pressure <120 vs. <140 mm Hg).^236^ This study reported no data on MCI or CATD outcomes. Despite achieving substantial separation between the groups in systolic blood pressure at 40 months (119.0 vs. 133.2 mm Hg), there was no significant difference between treatment groups at 40 months in brief cognitive screening tests, executive/attention/processing speed, or memory. The study reported results for the measure of change in MRI total brain volume between baseline and 40 months, but these results were not analyzed for this review because attrition exceeded 20 percent in one of the treatment groups. This study reported no data on adverse events. There were no consistent between treatment group differences in change in cognitive performance from baseline as a function of baseline age, gender, executive/attention/processing speed, history of cardiovascular disease, or diabetes duration.

### Antihypertensive Medication Treatments Versus Each Other

Eight RCTs met eligibility criteria, had low to medium risk of bias, compared different antihypertensive medication treatment regimens versus each other, and reported cognitive outcomes.^218, 220–222, 227, 230, 235, 237^ Only four of the eight trials reported any entry criteria that could relate to cognition. Of these, one study required that participants have some executive dysfunction (CLOX1 clock draw <10) but excluded those with dementia or an MMSE of <20,^227^ another excluded participants with either a mental disorder or any “clinically relevant chronic disease,”^237^ another excluded participants receiving any psychotropic drug that might interfere with cognition,^221^ and a fourth study excluded individuals with a stroke in the last 6 months.^222^ Baseline MMSE scores ranged from a mean of 23^235^ to a median of 29.^218^

None of these studies reported data on MCI or CATD outcomes.

One trial reported incident cognitive impairment, which it defined as a composite of incident dementia, incident cognitive impairment, or MMSE <24 in patients without baseline cognitive impairment.^218^ During a mean follow-up of 4.7 years, incident cognitive impairment occurred in 8 percent, 7 percent, and 8 percent of participants allocated to ACE inhibitor, ARB, and their combination, respectively. This corresponded to an odds ratio (OR) of 0.95 (95% CI, 0.85–1.07) for combination group versus the ACE inhibitor group and an OR of 0.90 (95% CI, 0.80–1.01) for the ARB group versus the ACE inhibitor group. Authors did not directly compare results between the ARB and combination groups.

All eight trials reported at least one cognitive performance outcome.^218, 220–222, 227, 230, 235, 237^ Three reported results for a change in a brief cognitive screening test (MMSE).^62, 218, 230, 235^ Two studies found no difference between their different antihypertensive medication treatment arms, in mean MMSE score at follow-up,^230^ or incidence of >3 point decline in MMSE.^218^ In one study, while individuals randomized to thiazide had no significant improvement in MMSE between baseline and 26 months, those assigned to ARB had a significant improvement in this outcome during that time period.^235^ No direct between-group comparison was reported.

Two studies found no difference in executive/attention/processing speed tests between their different antihypertensive medication treatment arms.^220, 222^ Three studies reported results for memory tests and found mixed results.^220–222^ One study found no difference on the Paired Association Learning Test (PALS) after 9 months follow-up between a group assigned a beta blocker and a group assigned a thiazide-potassium sparing diuretic combination.^220^ In another trial, participants randomized to ARB performed significantly better at 6 months than those assigned to beta blocker on both immediate and delayed recall of a word list.^221^ In a third trial, participants randomized to ARB plus thiazide performed no differently at 6 months than those assigned to ACE inhibitor plus thiazide group on immediate recall of a word list, but performed significantly better on delayed recall of the word list.^222^

None of these studies reported data on biomarkers.

Four of these studies reported adverse events outcomes.^221, 222, 227, 237^ In one study, participants assigned to methyldopa were significantly more likely than those assigned to a calcium channel blocker to experience any adverse event, a sleep disorder, or a sexual disorder, while incidence of life-threatening events, and of headache, fatigue, and cardiovascular or gastrointestinal side effects were similar between these two antihypertensive treatment groups.^237^ In another, participants randomized to ARB were significantly less likely to have an adverse event than those assigned to beta blocker.^221^ In another trial, there was no significant difference in risk of any adverse event (2.6 percent vs. 5.5 percent) between individuals randomized to ARB plus thiazide and those assigned to ACE inhibitor plus thiazide.^222^ In the fourth trial, there was no significant difference in risk of nonelective hospitalizations or other selected adverse events (dizziness, weakness or fatigue, noninjurious fall, cough) between individuals randomized to ACE inhibitor, ARB, or thiazide treatment groups.^227^

The ONTARGET study (ACE inhibitor vs. ARB vs. combination) was the only one of the eight eligible RCTs comparing one antihypertensive medication treatment versus another that reported subgroup analyses.^218^ Authors stated that they found no significant differential effects of treatment on cognitive outcomes in patient subgroups defined by age, history of hypertension, or previous stroke or TIA, although they presented no data for these analyses.

## Adults With MCI

Just one antihypertensive treatment trial, the HOPE study, met eligibility criteria, had low to medium risk of bias, and evaluated cognitive outcomes in participants categorized at baseline as having mild cognitive impairment.^233, 234^ This study randomized 81 older hypertensive adults to ACE inhibitor versus thiazide treatment and followed them for 6 months. Participants were hypertensive, yet had never received prior antihypertensive treatment. They were defined as having a “mild degree of cognitive impairment” based on a baseline MMSE of 20–28 (mean baseline MMSE was 26.1). No information was provided about participant education. Mean age was 76 years. This study reported no data on CATD outcomes. The treatment showed no effect in a model of all cognitive tests at all time-points, including two measures of executive/attention/processing speed and four measures of memory. This study reported no data on biomarker outcomes or adverse events. The study did not report any subgroup analyses. Evidence was insufficient to draw conclusions due to limited data (single study, n<500).

## Interpreting the Findings

Though one trial of stepped multiple agent antihypertensive regimen found a statistically significant reduction in incident CATD, the Syst-Eur trial,^223, 224^ it was a large study in which incident dementia was a relatively rare secondary outcome, and the three other trials that compared antihypertensive treatment versus placebo and reported an incident dementia outcome found no difference between treatment groups. We also found low-strength evidence of no difference between different antihypertensive treatment regimens on cognitive performance. However, these results should be interpreted in light of the fact that many trials were probably too short in duration to observe a clinically meaningful change in cognitive function in the middle-aged and older, and largely cognitively normal participants. Though extensive observational data suggest that midlife but not late-life hypertension is associated with a significant increase in risk of dementia,^242^ the minimal subgroup data reported from RCTs suggested that there was no difference in the effect of antihypertensive medication treatment on cognition based on participant age.

* Note that the literature currently does not use the term CATD; we specified whenever the diagnosis of dementia was defined.