# 4G Results: Vitamin Interventions

## Key Messages

- Moderate-strength evidence shows no benefit in cognitive performance for vitamin E in women.
- There was some signal that B_12_ plus folic acid may benefit brief cognitive test performance and memory but not executive function/attention/processing speed.
- Low-strength evidence for folic acid (0.4 mg) plus vitamin B_12_ (0.1–0.5 mg) shows benefit in brief cognitive test performance and memory.
- Moderate-strength evidence shows no benefit for folic acid (0.4 mg) and B_12_ (0.1–0.5 mg) versus placebo for executive/attention/processing speed.
- Low-strength evidence for vitamin B_12_ (0.02–0.5 mg), B_6_ (3–10 mg), and folate (0.56–1 mg) shows no benefit for executive/attention/processing speed.
- Low-strength evidence shows no benefit in cognitive performance for multivitamins, vitamin B with omega-3, vitamin C (in women), vitamin D with calcium (in women), or beta carotene (in women).
- Low-strength evidence shows no benefit in incident MCI or clinical Alzheimer’s-type dementia (CATD)^*^ for multivitamins or vitamin D with calcium.
- In adults with mild cognitive impairment (MCI), low-strength evidence shows no benefit for vitamin E in incident CATD.

## Eligible Studies

We identified 29 eligible publications reporting 24 unique studies of vitamin interventions to prevent age-related cognitive decline, MCI, or CATD.^98, 101, 102, 191–217^ Ten were assessed as high risk of bias and not used in our analysis. Of the remaining 19 publications of 16 unique studies, we analyzed the efficacy and comparative effectiveness of vitamin interventions separately for adults with normal cognition and those with MCI. Appendix L provides evidence tables, summary risk of bias assessments, and assessments of strength of evidence for key comparisons and outcomes.

## Logic of Vitamin Interventions

The logic underlying vitamin use varies with the vitamin. In the case of B vitamins the targeted pathway may involve lowering of homocysteine levels.

## Adults With Normal Cognition

### Efficacy: Vitamins Versus Inactive Control (Placebo)

Twelve randomized controlled trials (RCTs) with low or moderate risk of bias compared vitamins to inactive control (placebo) in adults with normal cognition.^101, 196–199, 201, 202, 205, 208–210, 212^ Total sample sizes ranged from 220 to 20,536. Conclusions are summarized in Table 4G.1 and individual study results are shown in Table 4G.2.

Table 4G.1 Conclusions: Vitamins versus placebo in adults with normal cognition

Comparison | Outcome | Conclusion | Strength of Evidence (justification)
Multivitamin vs. placebo k=4 | Dementia | No statistically significant difference in dementia diagnosis with multivitamins versus placebo long-term (n=20,469; 5 years). | Low (medium study limitations, imprecise, unknown consistency)
Multivitamin vs. placebo k=4 | MCI | No statistically significant difference in MCI diagnosis with multivitamins versus placebo long-term (n=20,469; 5 years). | Low (medium study limitations, imprecise, unknown consistency)
Multivitamin vs. placebo k=4 | Brief cognitive test performance | Unable to draw conclusion. | Insufficient (medium study limitations, indirect, imprecise, unknown consistency)
Multivitamin vs. placebo k=4 | Multidomain neuropsychological performance | No benefit in multidomain neuropsychological performance with multivitamins versus placebo (n=5,296; followup time unclear). | Low (medium study limitations, indirect, precise, unknown consistency)
Multivitamin vs. placebo k=4 | Executive/Attention/Processing speed | No benefit in executive/attention/processing speed with multivitamins versus placebo (n=992; up to 1 year). | Low (low-medium study limitations, indirect, precision unclear)
Multivitamin vs. placebo k=4 | Memory | No benefit in memory with multivitamins versus placebo (n=5,516; followup time unclear). | Low (low-medium study limitations, indirect, imprecise)
Folic acid vs. placebo k=1 | Dementia | No data available. | Insufficient (no data)
Folic acid vs. placebo k=1 | MCI | No data available. | Insufficient (no data)
Folic acid vs. placebo k=1 | Brief cognitive test performance | No data available. | Insufficient (no data)
Folic acid vs. placebo k=1 | Multidomain neuropsychological performance | Unable to draw conclusion. | Insufficient (low study limitations, indirect, precise, unknown consistency)
Folic acid vs. placebo k=1 | Executive/Attention/Processing speed | Unable to draw conclusion. | Insufficient (low study limitations, indirect, imprecise, inconsistent)
Folic acid vs. placebo k=1 | Memory | Unable to draw conclusion. | Insufficient (low study limitations, indirect, unknown consistency)
Folic acid + B_12_ vs. placebo k=2 | Dementia | No data available. | Insufficient (no data)
Folic acid + B_12_ vs. placebo k=2 | MCI | No data available. | Insufficient (no data)
Folic acid + B_12_ vs. placebo k=2 | Brief cognitive test performance | Unable to draw conclusion. | Insufficient (low study limitations, indirect, inconsistent)
Folic acid + B_12_ vs. placebo k=2 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
Folic acid + B_12_ vs. placebo k=2 | Executive/Attention/Processing speed | No benefit for executive/attention/processing speed test performance with folic acid (0.4 mg) and B_12_ (0.1–0.5 mg) compared to placebo (n=3,456; up to 2 years). | Medium (low study limitations, indirect, precision unclear)
Folic acid + B_12_ vs. placebo k=2 | Memory | Folic acid (0.4 mg) and B_12_ (0.1–0.5 mg) improved memory versus placebo (n=3,456; up to 2 years). | Low (low study limitations, indirect, imprecise)
Folate + B_6_ + B_12_ vs. placebo k=2 | Dementia | No data available. | Insufficient (no data)
Folate + B_6_ + B_12_ vs. placebo k=2 | MCI | No data available. | Insufficient (no data)
Folate + B_6_ + B_12_ vs. placebo k=2 | Brief cognitive test performance | No benefit for brief cognitive test performance with folate (0.56–1.0mg), B_6_ (3–10mg) and B_12_ (0.2–0.5mg) compared to placebo (n=1,124; up to 4 years). | Low (low study limitations, indirect)
Folate + B_6_ + B_12_ vs. placebo k=2 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
Folate + B_6_ + B_12_ vs. placebo k=2 | Executive/Attention/Processing speed | Unable to draw conclusion. | Insufficient (low study limitations, indirect, imprecise, inconsistent)
Folate + B_6_ + B_12_ vs. placebo k=2 | Memory | No benefit for memory with folate (0.56–1.0mg), B_6_ (3–10mg) and B_12_ (0.2–0.5mg) compared to placebo (n=1,124; up to 4 years). | Low (low study limitations, indirect, imprecise)
Vitamin E vs. placebo k=2 | Dementia | No data available. | Insufficient (no data)
Vitamin E vs. placebo k=2 | MCI | No data available. | Insufficient (no data)
Vitamin E vs. placebo k=2 | Brief cognitive test performance | No benefit for women in brief cognitive test performance with vitamin E (400–600mg) versus placebo long term (n=7,497; 4 years). | Moderate (low-medium study limitations, indirect)
Vitamin E vs. placebo k=2 | Multidomain neuropsychological performance | No benefit for women in multidomain neuropsychological performance with vitamin E versus placebo long term (n=7,497; 4 years). | Moderate (low-medium study limitations, indirect)
Vitamin E vs. placebo k=2 | Executive/Attention/Processing speed | No data available. | Insufficient (no data)
Vitamin E vs. placebo k=2 | Memory | No benefit for women in memory with vitamin E versus placebo long term (n=7,497; 4 years). | Moderate (low-medium study limitations, indirect t)
Vitamin C vs. placebo k=1 | Dementia | No data available. | Insufficient (no data)
Vitamin C vs. placebo k=1 | MCI | No data available. | Insufficient (no data)
Vitamin C vs. placebo k=1 | Brief cognitive test performance | No benefit for women in brief cognitive test performance with vitamin C versus placebo in long term (n=2,271; 4 years). | Low (low-medium study limitations, indirect, imprecise, unknown consistency)
Vitamin C vs. placebo k=1 | Multidomain neuropsychological performance | No benefit for women in multidomain neuropsychological performance with vitamin C versus placebo long term (n=2,271; 4 years). | Low (low-medium study limitations, indirect, imprecise, unknown consistency)
Vitamin C vs. placebo k=1 | Executive/Attention/Processing speed | No data available. | Insufficient (no data)
Vitamin C vs. placebo k=1 | Memory | No benefit for women in memory with vitamin C versus placebo long term (n=2,471; 4 years). | Low (low-medium study limitations, indirect, imprecise, unknown consistency)
Vitamin D + calcium vs. placebo k=1 | Dementia | No statistically significant difference in pooled dementia and MCI diagnosis with vitamin D and calcium versus placebo long term (n=4,122; 7 years). | Low (low-medium study limitations, unknown consistency)
Vitamin D + calcium vs. placebo k=1 | MCI | See above.
Vitamin D + calcium vs. placebo k=1 | Brief cognitive test performance | Unable to draw conclusion. | Insufficient (low-medium study limitations, indirect, imprecise, unknown consistency)
Vitamin D + calcium vs. placebo k=1 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
Vitamin D + calcium vs. placebo k=1 | Executive/Attention/Processing speed | No benefit for women in executive/attention/processing speed with vitamin D and calcium versus placebo long term (n=4,122; 7 years). | Low (low-medium study limitations, indirect, unknown consistency)
Vitamin D + calcium vs. placebo k=1 | Memory | No benefit for women in memory with vitamin D and calcium versus placebo long-term (n=4,122; 7 years). | Low (low-medium study limitations, indirect, imprecise)
Beta carotene vs. placebo k=1 | Dementia | No data available. | Insufficient (no data)
Beta carotene vs. placebo k=1 | MCI | No data available. | Insufficient (no data)
Beta carotene vs. placebo k=1 | Brief cognitive test performance | No benefit for women in brief cognitive test performance with beta carotene versus placebo long term (n=2,271; 4 years). | Low (low-medium study limitations, indirect, imprecise, unknown consistency)
Beta carotene vs. placebo k=1 | Multidomain neuropsychological performance | No benefit for women in multidomain neuropsychological performance with beta carotene versus placebo long term (n=2,271; 4 years). | Low (low-medium study limitations, indirect, , unknown consistency)
Beta carotene vs. placebo k=1 | Executive/Attention/Processing speed | No data available. | Insufficient (no data)
Beta carotene vs. placebo k=1 | Memory | No benefit for women in memory with beta carotene versus placebo long term (n=2,271; 4 years). | Low (low-medium study limitations, indirect, unknown consistency)

B_6_=vitamin B_6_; B_12_=vitamin B_12_; k=number of studies included; MCI=mild cognitive impairment; mg=milligrams; n=sample size; vs.=versus

Table 4G.2 Results overview: Vitamins versus inactive comparisons (placebo) in adults with normal cognition

Author Year Comparison N= Followup | Diagnosis | Brief Cognitive Test Performance/Multidomain Neuropsychological Test Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
Multivitamin Results Summary k=4; n=20,536 | 0 of 2 (no difference) k=1 | 0 of 3 (no difference) k=2 | 0 of 3 (no difference) k=2 | 0 of 2 (no difference) k=2 | 0 of 8 (no difference)
Grodstein, 2013^196^ Multivitamin vs. placebo n=5,947 (men) | | BCT NS [TICS] | | NS [Composite^b^] | 0 of 3 (no difference) | NR
Grodstein, 2013^196^ Multivitamin vs. placebo n=5,947 (men) | | MNP NS [Composite^a^]
McNeill, 2007^202^ Micronutrient supplement vs. placebo n=910 1 year | | | NS [DS Forward] | | 0 of 1 (no difference) | NR
Wolters, 2005^210^ Multivitamin vs. placebo n=220 (women) 6 months | | | NS [Kurztest fuer Allgemeine Intelligenz] | NS [Berliner Amnesit Test] | 0 of 3 (no difference) | NR
Wolters, 2005^210^ Multivitamin vs. placebo n=220 (women) 6 months | | | NS [WAIS-III Symbol Search]
Heart Protection Study, 2002^197^ Vitamin C + B vitamins + beta carotene vs. placebo n=20,536 5 years | NS [Dementia] | BCT NS [TICS] | | | 0 of 3 (no difference) | NR
Heart Protection Study, 2002^197^ Vitamin C + B vitamins + beta carotene vs. placebo n=20,536 5 years | NS [MCI]
B Vitamins: Folic Acid Results Summary k=1; n=818 | | MNP 1 of 1 favor I k=1 | 1 of 3 favor I k=1 | 1 of 1 favor I k=1 | 2 of 4 favor I
Durga, 2007^212^ B vitamins: folic acid vs. placebo n=818 3 years | | MNP I>C [Composite] | I>C [DSST] | I>C [RAVLT] | 3 of 5 favor I | NR
Durga, 2007^212^ B vitamins: folic acid vs. placebo n=818 3 years | | | NS [SCWT]
Durga, 2007^212^ B vitamins: folic acid vs. placebo n=818 3 years | | | NS [Concept Shifting Test]
B Vitamins: Folic Acid + B_12_ Results Summary k=2; n=3,819 | | BCT 2 of 2 favor I k=2 | 0 of 11 (no difference) k=2 | 2 of 7 favor I k=2 | 2 of 18 favor I
van der Zwaluw, 2014^208^ B vitamins: folic acid + B_12_ vs. placebo n=2,919 2 years | | BCT I>C [MMSE] | NS [Composite^c^] | NS [Composite^f^] | 1 of 14 favor I | NR
van der Zwaluw, 2014^208^ B vitamins: folic acid + B_12_ vs. placebo n=2,919 2 years | | | NS [Composite^d^] | NS [RAVLT Immediate Recall]
van der Zwaluw, 2014^208^ B vitamins: folic acid + B_12_ vs. placebo n=2,919 2 years | | | NS [Composite^e^] | NS [RAVLT Delayed Recall]
van der Zwaluw, 2014^208^ B vitamins: folic acid + B_12_ vs. placebo n=2,919 2 years | | | NS [DS Forward] | NS [RAVLT Recognition]
van der Zwaluw, 2014^208^ B vitamins: folic acid + B_12_ vs. placebo n=2,919 2 years | | | NS [TMT A]
van der Zwaluw, 2014^208^ B vitamins: folic acid + B_12_ vs. placebo n=2,919 2 years | | | NS [TMT B]
van der Zwaluw, 2014^208^ B vitamins: folic acid + B_12_ vs. placebo n=2,919 2 years | | | NS [SCWT 1 & 2]
van der Zwaluw, 2014^208^ B vitamins: folic acid + B_12_ vs. placebo n=2,919 2 years | | | NS [SCWT Interference]
van der Zwaluw, 2014^208^ B vitamins: folic acid + B_12_ vs. placebo n=2,919 2 years | | | NS [SDMT]
Walker, 2012^209^ B vitamins: folic acid + B_12_ vs. placebo n=900 2 years | | BCT I>C [TICS Total] | NS [TICS Orientation/Calculation] | I>C [TICS Immediate Recall] | 3 of 6 favor I | NR
Walker, 2012^209^ B vitamins: folic acid + B_12_ vs. placebo n=900 2 years | | | NS [TICS Attention] | I>C [TICS Delayed Recall]
Walker, 2012^209^ B vitamins: folic acid + B_12_ vs. placebo n=900 2 years | | | | NS [TICS Semantic Memory]
B Vitamins: Folate + B_6_ + B_12_ Results Summary k=2; n=1,524 | | BCT 0 of 2 (no difference) k=2 | 1 of 2 favor C k=2 | 0 of 4 (no difference) k=2 | 1 of 8 favor C
Andreeva, 2011^101^ B vitamins: folate + B_6_ + B_12_ vs. placebo n=1,248 4 years | | BCT NS [TICS] | | NS [TICS Memory] | 0 of 3 (no difference) | NR
Andreeva, 2011^101^ B vitamins: folate + B_6_ + B_12_ vs. placebo n=1,248 4 years | | | | NS [TICS Recall]
McMahon, 2006^201^ B vitamins: folate + B_6_ + B_12_ vs. placebo n=276 2 years | | BCT NS [MMSE] | NS [RCPM] | NS [RAVLT] | 1 of 5 favor C | NR
McMahon, 2006^201^ B vitamins: folate + B_6_ + B_12_ vs. placebo n=276 2 years | | | C>I [TMT B] | NS [Paragraph Recall]
Vitamin E Results Summary k=2; n=9,201 | | BCT 0 of 2 (no difference) k=2 MNP 0 of 2 (no difference) k=2 | | 0 of 2 (no difference) k=2 | 0 of 6 (no difference) | None k=1
Kang, 2009^199^ Vitamin E vs. placebo n=2,824 9 years treatment 5 years followup | | BCT NS [TICS] | | NS [Composite] | 0 of 3 (no difference) | None
Kang, 2009^199^ Vitamin E vs. placebo n=2,824 9 years treatment 5 years followup | | MNP NS [Composite]
Kang, 2006^198^ Vitamin E vs. placebo n=6,377 10 years treatment 4 years followup | | BCT NS [TICS] | | NS [Composite] | 0 of 3 (no difference) | NR
Kang, 2006^198^ Vitamin E vs. placebo n=6,377 10 years treatment 4 years followup | | MNP NS [Composite]
Vitamin C Results Summary k=1; n=2,824 | | BCT 0 of 1 (no difference) k=1 MNP 0 of 1 (no difference) k=1 | | 1 of 1 favor I k=1 | 1 of 3 favor I | None k=1
Kang, 2009^199^ Vitamin C vs. placebo n=2,824 9 years treatment 5 years followup | | BCT NS [TICS] | | I>C [Composite] | 1 of 3 favor I | None
Kang, 2009^199^ Vitamin C vs. placebo n=2,824 9 years treatment 5 years followup | | MNP NS [Composite]
Vitamin D + Calcium Results Summary k=1; n=4,143 | 0 of 1 (no difference) k=1 | BCT k=1 0 of 1 (no difference) | 0 of 1 (no difference) k=1 | 0 of 2 (no difference) k=1 | 0 of 4 (no difference)
Rossom, 2012^205^ Vitamin D + calcium vs. placebo n=4,143 8 years | NS [Probable Dementia or MCI] | BCT NS [MMSE] | NS [DS Forward & Backward (pooled)] | NS [CVLT] | 0 of 5 (no difference) | NR
Rossom, 2012^205^ Vitamin D + calcium vs. placebo n=4,143 8 years | | | | NS [BVRT]
Beta carotene Results Summary k=1; n=2,824 | | BCT 0 of 1 (no difference) k=1 MNP 0 of 1 (no difference) k=1 | | 0 of 1 (no difference) k=1 | 0 of 3 (no difference) | None k=1
Kang, 2009^199^ Vitamin C vs. placebo n=2,824 9 years treatment 5 years followup | | BCT NS [TICS] | | NS [Composite] | 0 of 3 (no difference) | None
Kang, 2009^199^ Vitamin C vs. placebo n=2,824 9 years treatment 5 years followup | | MNP NS [Composite]

a mean multidomain battery composite z score composed of TICS, EBMT, TICS 10-word list delayed recall, and category fluency;

b composite z score of TICS and EBMT immediate and delayed word recall;

c composite z score of Attention and working memory (Digit Span Forward & Backward);

d composite z score of Information Processing Speed (Trails A, Stroop I & II);

e composite z score of Executive functioning (Trails B, Stroop Interference, Verbal fluency);

f composite z score of Episodic memory (RAVLT immediate recall, decay, recognition)

B_6_=vitamin B_6_; B_12_=vitamin B_12_; BCT=brief cognitive screening test; BVRT=Benton Visual Retention Test; C=inactive control; CVLT=California Verbal Learning Test; DS=Digit Span (Forward and/or Backward); DSST=Digit Symbol Substitution Test; I=intervention; k=number of studies included; MCI=mild cognitive impairment; MMSE=Mini-Mental State Examination; MNP=multidomain neuropsychological test performance; n=sample size; NR=not reported; NS=no statistically significant difference; RAVLT=Rey Auditory Verbal Learning Test; RCPM= Raven’s Colored Progressive Matrices; SCWT=Stroop Color Word Test; SDMT=Symbol Digit Modalities Test; TICS=Telephone Interview for Cognitive Status; TMT=Trail Making Test (Part A and/or B); vs.=versus; WAIS=Wechsler Adult Intelligence Scale

Shading indicates summary rows and columns.

#### Multivitamins

Four RCTs (n=27,613) with low or moderate risk of bias compared multivitamins with placebo. Multivitamin interventions included varying doses and combinations of vitamin A, B vitamins, vitamin C, vitamin D, vitamin E, beta carotene, biotin, cobalamin, copper, folic acid, iodine, iron, magnesium, manganese, niacin, panthothenic acid, pyridoxine, riboflavin, selenium, thiamine, and zinc.^196, 197, 202, 210^ Participants varied; studies included physicians over 65,^196^ women over 60,^210^ adults at serious risk of death from heart disease aged 40 to 80,^197^ and adults over 65.^202^ Study samples were large, ranging from 1,130 to 20,536, and duration ranged from 6 months to 8.5 years.

Low-strength evidence from one trial (n=20,536) shows no difference for diagnosis of either MCI or CATD over a 5-year period.^197^

In general, low-strength evidence showed no statistical differences on cognitive performance tests, including multidomain neuropsychological performance,^196^ executive/attention/processing speed,^202, 210^ or memory.^196, 210^ Evidence was insufficient for brief cognitive test performance.

None of the trials comparing multivitamins to placebo reported serious adverse effects.

Overall, no differences were found in subgroup analyses. Three trials assessed the effects of lifestyle factors on the effect of multivitamins.^196, 202, 210^ Cognitive results did not differ by the lifestyle factors of history of smoking, alcohol use, fruit and vegetable intake or nutritional deficiency.

Two trials assessed the effect of baseline cognition and education, prior supplement use, and comorbidities.^196, 210^ Final cognitive or diagnostic results did not differ by cognitive performance at baseline, school graduation and job training. Final cognitive results also did not differ by status of BMI, diabetes, hypertension, hyperlipidemia or depression, or prior use of folates, hormone replacement therapy, or vitamin status.

#### B Vitamins: Folic Acid

One study (n=818) compared folic acid to placebo.^212^ Participants took folic acid (0.8mg) or matching placebo for 3 years. People aged 50–70 with high homocysteine levels likely caused by suboptimal folate concentrations were recruited.

Durga et al. did not report diagnostic outcomes, brief cognitive test performance, or adverse effects. Evidence was insufficient to determine improvement with folic acid for multidomain neuropsychological performance, executive/attention/processing speed, or memory.

#### B Vitamins: Folic Acid and B_12_

Two studies (n=3,819) compared folic acid and B_12_ to placebo. ^208, 209^ Participants took folic acid (0.4mg) and B_12_ (0.1–0.5mg) or a matching placebo for 2 years. One study specifically addressed persons with elevated homocysteine levels of at least 12 micromoles/liter (presumed vitamin deficiency status).^208^ Studies recruited adults aged 65+ ^208^ and sedentary adults aged 60–74 with elevated psychological distress.^209^

Neither trial reported diagnostic outcomes, multidomain neuropsychological performance, or adverse effects. Both trials reported brief cognitive test performance (n=3,819). Evidence was insufficient to conclude possible effects.

Both studies reported 11 tests assessing the effect of folic acid/B_12_ on executive/attention/processing speed.^208, 209^ None showed statistically significant improvement with folic acid/B_12_ over placebo (medium-strength of evidence).

Both studies reported seven tests assessing the effect of folic acid/B_12_ on memory.^208, 209^ Only two of seven tests showed statistically significant improvement with folic acid/B_12,_ and the effect sizes were small. Walker et al. reported a Telephone Interview for Cognitive Status (TICS) time by intervention effect size of 0.15 for immediate recall and 0.18 for delayed recall, again (low-strength evidence).^209^

Regarding subgroup analyses, benefit on memory for folic acid/B_12_ compared to placebo was reported for participants with low holotranscobalamin levels.^208^

#### B Vitamins: Folate, B_6_, and B_12_

Two studies (n=1,524) compared folate, B_6_ and B_12_ to placebo.^101, 201^ Participants took folate (0.56–1.0 mg), B_6_ (3–10 mg) and B_12_ (0.2–0.5 mg) or matching placebo for 2 to 4 years. One trial also randomized participants to folate/B_6_/B_12_ with omega-3 versus placebo and folate/B_6_/B_12_ versus omega-3; these results are discussed below in comparative efficacy.^101^ Studies recruited adults aged 45–70 with heart disease,^101^ and adults aged 65+ with healthy cognition and homocysteine levels at least 13 micromoles/liter. ^201^

Neither trial reported diagnostic outcomes, multidomain neuropsychological performance, or adverse effects. The studies reported two tests assessing the effect of folate/B_6_/B_12_ on brief cognitive test performance; neither were statistically significant with intervention (low-strength evidence).

One study reported two tests assessing the effect of folate/B_6_/B_12_ on executive/attention/processing speed, but evidence was insufficient to conclude possible effects.^201^

Both studies reported four tests assessing the effect of folate/B_6_/B_12_ on memory.^101, 201^ None showed statistically significant improvement with folate/B_6_/B_12_ (low-strength evidence).

Subgroup analysis findings were mixed, finding no differences, or possible differences favoring either the placebo or folate/B_6_/B_12_. In particular, Andreeva et al. reported participants with a history of myocardial infarction/unstable angina receiving folate/B_6_/B_12_ had lower semantic memory scores (TICS-m subscore) compared to participants of the same age taking placebo (odds ratio: 1.70; 90% CI 1.16 to 2.51). Also, participants aged 65+ and receiving folate/B_6_/B_12_ had lower brief cognitive test performance scores (TICS-m) and recall memory scores (TICS-m subscore) compared to participants of the same age taking placebo (p<0.05).^101^

#### Vitamin E

Two trials (n=9,201) compared vitamin E with a placebo.^198, 199^ Both studies randomized women aged 65+ to vitamin E or placebo every other day. However, one randomized women to 600 IU (equivalent of about 400 mg) vitamin E for 10 years,^198^ while the other randomized women with cardiovascular disease or three or more coronary risk factors to 402 mg vitamin E for 9 years.^199^ Due to high attrition at longer-term followup time points, results were extracted for both studies at 4-year followup. Kang et al. also included an additional two arms, vitamin C and beta carotene, reported separately below.

Neither trial reported diagnostic outcomes or executive/attention/processing speed. Both trials provide moderate-strength evidence showing no differences between vitamin E compared with placebo at 4-year followup were found in brief cognitive test performance (two tests), multidomain neuropsychological performances (two tests), or memory (two tests).

Kang et al. did not observe adverse effects in either vitamin E or placebo group.^199^

Two trials assessed the effect of several participant characteristics on the effect of vitamin E.^198, 199^ Cognitive results did not differ by age, baseline cognition (baseline performance, highest attained education or perceived memory change), supplement use (antioxidants, multivitamins or hormone replacement therapy), comorbidities (body mass index (BMI), cardiovascular disease, diabetes, hypertension, hyperlipidemia or depression), or lifestyle factors (smoking, alcohol use, or exercise).

#### Vitamin C

Kang et al. (n=2,824) compared vitamin C with placebo.^199^ The trial randomized women aged 65+ with or at risk for cardiovascular disease to 500 mg of vitamin C or placebo daily for 9 years. The longest followup with low or moderate risk of bias was approximately 4 years after baseline cognitive assessments.

The trial did not report diagnostic outcomes or executive/attention/processing speed and provided low-strength evidence showing no statistically significant improvements with vitamin C for brief cognitive test performance or multidomain neuropsychological performances.^199^ One test assessing memory reported statistically significant improvement with vitamin C (author-created composite z-score between groups change from baseline: 0.07; 95% CI 0.0 to 0.13, p=0.05).^199^ However, the study did not correct for multiple comparisons, and given the small effect size these results were not likely to be clinically meaningful. No serious adverse effects were observed in either vitamin C or placebo arm.

Kang et al. assessed the effect of several participant characteristics on the effect of vitamin C.^199^ Only cognitive results differed by incident cardiovascular disease (p<0.01). Cognitive results did not differ by age, baseline cognition (baseline performance or highest attained education), supplement use (antioxidants or multivitamins), comorbidities (prior cardiovascular disease or associated risk factors), or lifestyle factors (smoking or alcohol use).

#### Vitamin D Plus Calcium

One trial (n=4,143) compared vitamin D with calcium to placebo.^205^ Participants in the Women’s Health Initiative Memory Study were previously randomized to 400 IU vitamin D_3_ with 1000 mg calcium or a matching placebo for a mean of 7.8 years. People in the intervention group were also allowed to take an additional supplement containing 1000 mg calcium with 600 mg vitamin D. Followup assessment took place at approximately 7.8 years.

Rossom et al. did not report multidomain neuropsychological performances or adverse effects.^205^ Low-strength evidence shows diagnosis of probable dementia or MCI, reported as one pooled outcome, did not differ statistically between vitamin and placebo groups. Evidence was insufficient to conclude differences between vitamin D and calcium versus placebo for brief cognitive test or multidomain neuropsychological performance. One test assessed executive/attention/processing speed and two tests assessed memory; all showed no statistically significant difference with vitamin D and calcium.

#### Beta Carotene

Kang et al. (n=2,824) compared beta carotene with placebo.^199^ Women aged 65+ with or at risk for cardiovascular disease were randomized to 50 mg beta carotene or placebo every other day for 9 years. The longest followup with low or moderate risk of bias was approximately 4 years after baseline cognitive assessments.

Kang et al. did not report diagnostic outcomes or executive/attention/processing speed.^199^ Low-strength evidence shows no statistically significant improvements with beta carotene for brief cognitive test performance (one test), multidomain neuropsychological performances (one test), or memory (one test). No serious adverse effects were observed in either beta carotene or placebo arm.

One trial assessed the effect of several participant characteristics on the effect of beta carotene.^199^ Only one variable was significant; cognitive results differed by dietary antioxidant intake (p=0.02). Cognitive results did not differ by age, baseline cognition (baseline performance or highest attained education), multivitamin use, comorbidities (cardiovascular disease or associated risk factors), or lifestyle factors (smoking or alcohol use).

### Comparative Effectiveness: Vitamins Versus Active Comparison

One RCT (n=167) compared vitamins with an active control group.^216^ Stott et al. analyzed the comparative effectiveness of varying combinations of B vitamins (folic acid/B_12_ vs. B_2_ vs. B_6_ vs. folic acid/B_12_/B_2_ vs. folic acid/B_12_/B_6_ vs. B_2_/B_6_ vs. folic acid/B_12_/B_2_/B_6_). They randomized people aged 65+ with a history of ischemic vascular disease to the above combinations of 2.5 mg folic acid, 25 mg B_2_, 25 mg B_6_, and/or 0.4 mg B_12_ daily for 3 months. Cognitive outcomes were assessed at 6 and 12 months. The sample size for this unique comparison was too small to assess strength of evidence. See Table 4G.3 for summary of results.

Table 4G.3 Results overview: Vitamins versus active comparisons in adults with normal cognition

Author Year Comparison N= Followup | Diagnosis | Brief Cognitive Test Performance/Multidomain Neuropsychological Test Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
B vitamins Combinations ^ * ^ Results Summary k=1; n=167 | | BCT 0 of 1 (no difference) k=1 | 0 of 1 (no difference) k=1 | | 0 of 2 (no difference)
Stott, 2005^216^ B vitamins combinations (folic acid, B_2_, B_6_, B_12_) n=167 1 year | | BCT NS [TICS-M] | NS [SDMT] | | 0 of 2 (no difference) | NR

* Participants randomized to one of 7 combinations: 1) folic acid/B_12_ 2) B_2_ 3) B_6_ 4) folic acid/B_12_/B_2_ 5) folic acid/B_12_/B_6_ 6) B_2_/B_6_ 7) folic acid/B_12_/B_2_/B_6_. None were significantly different for any outcome.

B_2_=vitamin B_2_; B_6_=vitamin B_6_; B_12_=vitamin B_12_; BCT=brief cognitive test performance; k=number of studies included; n=sample size; NR=not reported; NS=no statistically significant difference; SDMT=Symbol Digit Modalities Test; TICS-M=Telephone Interview for Cognitive Status-Modified

Shading indicates summary rows and columns.

Other studies that used B vitamins as components of active controls can be found in Chapter 4C.

## Adults With MCI

### Efficacy: Vitamins Versus Inactive Control

Three trials reported in six publications (n=1,038) with low or moderate risk of bias compared vitamins with inactive control (placebo) in adults with MCI.^191, 194, 195, 203, 213, 215^ Total sample sizes ranged from 256 to 516. Strength of evidence was only assessed for one study with a sufficiently large sample size.^203^ Conclusions are summarized in Table 4G.4 and individual study results for all three trials are in Table 4G.5

Table 4G.4 Conclusions: Vitamins versus inactive comparisons in adults with MCI

Comparison | Outcome | Conclusion | Strength of Evidence (justification)
Multivitamin vs. placebo k=1 | Dementia | No data available. | Insufficient (no data)
Multivitamin vs. placebo k=1 | Brief cognitive test performance | Limited data. | Insufficient (limited data)
Multivitamin vs. placebo k=1 | Multidomain neuropsychological performances | No data available. | Insufficient (no data)
Multivitamin vs. placebo k=1 | Executive/Attention/Processing speed | No data available. | Insufficient (no data)
Multivitamin vs. placebo k=1 | Memory | No data available. | Insufficient (no data)
B Vitamins (folic acid/B_6_/B_12_) vs. placebo k=1 | Dementia | No data available. | Insufficient (no data)
B Vitamins (folic acid/B_6_/B_12_) vs. placebo k=1 | Brief cognitive test performance | Limited data. | Insufficient (limited data)
B Vitamins (folic acid/B_6_/B_12_) vs. placebo k=1 | Multidomain neuropsychological performances | No data available. | Insufficient (no data)
B Vitamins (folic acid/B_6_/B_12_) vs. placebo k=1 | Executive/Attention/Processing speed | No data available. | Insufficient (no data)
B Vitamins (folic acid/B_6_/B_12_) vs. placebo k=1 | Memory | Limited data. | Insufficient (limited data)
Vitamin E vs. placebo k=1 | Dementia | No statistically significant difference in CATD diagnosis with vitamin E versus placebo long term (n=516; 3 years). | Low (medium study limitations, imprecise)
Vitamin E vs. placebo k=1 | Brief cognitive test performance | Unable to draw conclusion. | Insufficient (medium study limitations, indirect, imprecise, unknown consistency)
Vitamin E vs. placebo k=1 | Multidomain neuropsychological performances | Unable to draw conclusion. | Insufficient (medium study limitations, indirect, precision unclear, unknown consistency)
Vitamin E vs. placebo k=1 | Executive/Attention/Processing speed | Unable to draw conclusion. | Insufficient (medium study limitations, indirect, imprecise, unknown consistency)
Vitamin E vs. placebo k=1 | Memory | Unable to draw conclusion. | Insufficient (medium study limitations, indirect, imprecise, unknown consistency)

B_6_=vitamin B_6_; B_12_=vitamin B_12_; k=number of studies included; MCI=mild cognitive impairment; n=sample size;

Table 4G.5 Results overview: Vitamins versus inactive comparisons in adults with MCI

Author Year Comparison N= Followup | Diagnosis | Brief Cognitive Test Performance/Multidomain Neuropsychological Test Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
Multivitamin Results Summary k=1; n=256 | | BCT 0 of 1 (no difference) k=1 | | | 0 of 1 (no difference)
Naeini, 2014^191^ Vitamin E + vitamin C vs. placebo n=256 1 year | | BCT NS [MMSE] | | | | NR
B vitamins: Folic acid + B_6_ + B_12_ Results Summary k=1; n=217 | | BCT 0 of 1 (no difference) k=1 | | 0 of 1 (no difference) k=1 | 0 of 2 (no difference)
Smith, 2010^207^ deJager, 2012(de Jager, 2012 #372} Douaud, 2013^195^ Oulhaj 2016^215^ B vitamins (folic acid + B_12_ + B_6_) vs. placebo n=217 2 years | | BCT NS [MMSE] | | NS [HVLT] | | NR
Vitamin E Results Summary k=1; n=516 | 0 of 2 (no difference) k=1 | BCT 0 of 1 (no difference) k=1 MNP 0 of 1 (no difference) k=1 | 0 of 1 (no difference) k=1 | 0 of 1 (no difference) k=1 | 0 of 4 (no difference) | 28% vs. 25%^*^; reasons NR
Petersen, 2005^203^ Vitamin E vs. placebo n=516 3 years | NS [CATD] | BCT NS [MMSE] | NS [Composite] | NS [Composite]
Petersen, 2005^203^ Vitamin E vs. placebo n=516 3 years | NS [CDR Sum of Boxes] | MNP NS [ADAS-Cog]

ADAS-Cog=Alzheimer’s Disease Assessment Scale-Cognitive Subscale; B_6_=vitamin B_6_; B_12_=vitamin B_12_; BCT=brief cognitive test performance; C=inactive control; CATD=clinical Alzheimer’s-type Dementia; CDR=Clinical Dementia Rating; HVLT=Hopkins Verbal Learning Test; k-number of studies included; I=intervention; MCI=mild cognitive impairment; MMSE=Mini-Mental State Examination; MNP=multidomain neuropsychological test performance; n=sample size; NR=not reported; NS=no statistically significant difference; vs.=versus

Shading indicates summary rows and columns.

One trial (n=516) compared vitamin E to placebo for preventing cognitive decline.^203^ They randomized adults aged 55–90 with degenerative amnestic MCI to 2000 IU vitamin E or placebo daily for 3 years. They study also included a donepezil arm, the results of which are discussed in the Chapter 4K.

Evidence was insufficient to determine improvement with vitamin E for brief cognitive test performance, multidomain neuropsychological performance, executive/attention/processing speed, or memory. Two tests assessed differences in diagnosis of CATD at 3 years and found low-strength evidence for no difference between groups. Serious adverse effects did not differ between groups.

## Interpreting the Findings

Overall, little to no benefit was shown with vitamin use in preventing cognitive decline. The only benefits noted were for folic acid plus B_12_ for memory versus placebo in adults with normal cognition; one of these studies administered high doses of folic acid and B_12_ in adults with elevated homocysteine levels. However, no benefit was found for folate, B_6_, B_12_ versus placebo for brief cognitive test performance or memory. The differences between studies could not be explained by dosage or deficiency state. Further, the positive results were in a small proportion of cognitive performance tests and of small effect size. Additionally, many of the vitamins were examined in a few studies that enrolled only women.

* Note that the literature currently does not use the term CATD; we specified whenever the diagnosis of dementia was defined.