# 4F Results: Hormone Therapy Interventions

## Key Messages

- Hormone therapy shows mixed results of harms and benefits.
- Low-strength evidence suggests that estrogen therapy may slightly increase the risk of probable mild cognitive impairment (MCI) and clinical Alzheimer’s-type dementia (CATD)^*^ when the two diagnostic categories are examined together.
- Low-strength evidence suggests that estrogen plus progestin therapy may slightly increase the risk of probable CATD.
- Low-strength evidence suggests that raloxifene may decrease the risk of MCI but not the risk of CATD or of a combined outcome of MCI or CATD compared to placebo.
- In addition to these outcomes, hormone therapy has been associated with serious adverse events, including increased risk of certain cancers and cardiovascular disease.

## Eligible Studies

We identified 44 eligible publications reporting 31 unique studies of hormone therapy interventions to prevent age-related cognitive decline, MCI, or CATD.^110, 145–186^ Eight studies were assessed as high risk of bias, resulting in 23 low or medium risk of bias studies used in our analysis.^110, 145–147, 152, 165, 169, 182^

Soy and red clover interventions are included in this section due to their phytoestrogenic properties. Not only do the soy and red clover interventions vary considerably from the hormone therapies included in this section, but also the hormone therapies differ from each other.

The majority of studies were designed to examine cognition as a primary outcome. Exceptions included ancillary studies of the longitudinal Women’s Health Initiative (WHI),^149, 152, 177–180^ two studies investigating the use of selective estrogen receptor modulators (SERMs) in preventing vertebral fractures,^169, 184^ two studies (three articles) on the use of hormones to prevent cardiovascular disease,^156, 158, 163^ and one study on the effects of testosterone on bone and muscle.^165^

We analyzed the efficacy and comparative effectiveness of hormone therapies separately for adults with normal cognition and those with MCI. Appendix K provides evidence tables, summary risk of bias assessments, and assessments of strength of evidence for key comparisons and outcomes.

## Logic of Hormone Therapy Interventions

Speculation is longstanding about the relationship between the pituitary endocrine axis and aging.^187^ While epidemiological studies have suggested that hormone replacement therapy may have a beneficial effect on cognition,^188^ randomized trials have produced inconsistent results, even suggesting in some cases that some hormone therapies may have a detrimental effect on cognition.^179, 180^ Although it is not precisely a hormone, we included soy in this section because it is often used by people in lieu of hormone replacement therapy.

## Adults With Normal Cognition

Conclusions are summarized in Table 4F.1 and individual study results in Table 4F.2.

Table 4F.1 Conclusions: Hormone therapies versus inactive comparisons in adults with normal cognition

Comparison | Outcome | Conclusion | Strength of Evidence (justification)
HRT-estrogen vs. inactive control k=6 | Dementia | Increased risk of probable dementia/MCI associated with estrogen therapy (n=2,947; 5–7 years) but no statistically significant difference in risk of probable dementia or MCI when diagnostic categories reported separately. | Low (medium study limitations, unknown consistency)
HRT-estrogen vs. inactive control k=6 | MCI | No statistically significant difference between estrogen therapy and placebo groups in risk of MCI (n=2,947; 5–7 years). | Low (medium study limitations, unknown consistency)
HRT-estrogen vs. inactive control k=6 | Brief cognitive test performance | Decreased performance in brief cognitive test performance with higher dose estrogen compared to placebo (n=3,364; 5–7 years). | Low (medium study limitations, indirect, imprecise)
HRT-estrogen vs. inactive control k=6 | Multidomain neuropsychological performance | Unable to draw conclusion. | Insufficient (medium study limitations, indirect, unknown consistency, imprecise)
HRT-estrogen vs. inactive control k=6 | Executive/Attention/Processing speed | No benefit with estrogen compared to placebo (n=2,056; 5–7 years) | Low (medium study limitations, indirect, imprecise)
HRT-estrogen vs. inactive control k=6 | Memory | No benefit with estrogen compared to placebo (n=2,056; 5–7 years) | Low (medium study limitations, indirect, imprecise)
HRT-estrogen + progestin vs. inactive control k=5 | Dementia | Increased risk of probable dementia associated with estrogen/progestin therapy (n=4,532; 5–7 years) but no statistically significant difference in risk of probable dementia or MCI when the diagnostic categories were combined. | Low (medium study limitations, unknown consistency)
HRT-estrogen + progestin vs. inactive control k=5 | MCI | No statistically significant difference between estrogen-progestin therapy and placebo in rates of MCI (n=4,532; 5–7 years) | Low (medium study limitations, unknown consistency)
HRT-estrogen + progestin vs. inactive control k=5 | Brief cognitive test performance | No benefit in brief cognitive test performance with estrogen/progestin versus placebo (n=6,100; up to 7 years). | Low (medium study limitations, indirect)
HRT-estrogen + progestin vs. inactive control k=5 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
HRT-estrogen + progestin vs. inactive control k=5 | Executive/Attention/Processing speed | No benefit in executive/attention/processing speed with estrogen/progestin versus placebo (n=3,007; up to 7 years) | Low (medium study limitations, indirect, imprecise)
HRT-estrogen + progestin vs. inactive control k=5 | Memory | Decreased memory performance with estrogen/progestin versus placebo (n=3,149; up to 7 years) | Low (medium study limitations, indirect, imprecise)
DHEA vs. inactive control k=1 | Dementia | No data available. | Insufficient (no data)
DHEA vs. inactive control k=1 | MCI | No data available. | Insufficient (no data)
DHEA vs. inactive control k=1 | Brief cognitive test performance | Limited data. | Insufficient (limited data)
DHEA vs. inactive control k=1 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
DHEA vs. inactive control k=1 | Executive/Attention/Processing speed | Limited data. | Insufficient (limited data)
DHEA vs. inactive control k=1 | Memory | Limited data. | Insufficient (limited data)
SERM vs. inactive control k=2 | Dementia | No statistically significant differences in risk of Alzheimer’s disease, any type of dementia, or “dementia or MCI” between 2 doses of raloxifene (60 mg and 120 mg) and placebo (n=5,386; 3 years) | Low (medium study limitations, unknown consistency)
SERM vs. inactive control k=2 | MCI | Slightly decreased risk of MCI in raloxifene compared to placebo (120mg but not 60 mg of raloxifene) (n=5,386; 3 years). | Low (medium study limitations, unknown consistency)
SERM vs. inactive control k=2 | Brief cognitive test performance | No data available. | Insufficient (no data)
SERM vs. inactive control k=2 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
SERM vs. inactive control k=2 | Executive/Attention/Processing speed | No benefit in executive/attention/processing speed with SERM versus placebo (n=5,877; 3 years) | Low (medium study limitations, indirect)
SERM vs. inactive control k=2 | Memory | No benefit in memory with SERM versus placebo (n=5,739; 3 years) | Low (medium study limitations, indirect)
Soy vs. inactive control k=5 | Dementia | No data available. | Insufficient (no data)
Soy vs. inactive control k=5 | MCI | No data available. | Insufficient (no data)
Soy vs. inactive control k=5 | Brief cognitive test performance | No benefit in brief cognitive test performance with soy versus placebo (n=393; 1 year). | Insufficient (medium study limitations, indirect, imprecise)
Soy vs. inactive control k=5 | Multidomain neuropsychological performance | No benefit in multidomain neuropsychological performance with soy versus placebo (n=393; 2.5 years) | Insufficient (medium study limitations, indirect, imprecise)
Soy vs. inactive control k=5 | Executive/Attention/Processing speed | No benefit with soy versus placebo (n=829; up to 2.5 years) | Low (medium study limitations, imprecise)
Soy vs. inactive control k=5 | Memory | No benefit with soy versus placebo (n=829; up to 2.5 years). | Low (medium study limitations imprecise)
Red clover vs. inactive control k=1 | Dementia | No data available. | Insufficient (no data)
Red clover vs. inactive control k=1 | MCI | No data available. | Insufficient (no data)
Red clover vs. inactive control k=1 | Brief cognitive test performance | No data available. | Insufficient (no data)
Red clover vs. inactive control k=1 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
Red clover vs. inactive control k=1 | Executive/Attention/Processing speed | Limited data. | Insufficient (limited data)
Red clover vs. inactive control k=1 | Memory | Limited data. | Insufficient (limited data)

DHEA=dehydroepiandrosterone; k=number of studies included; MCI=mild cognitive impairment; n=sample size; SERM= selective estrogen receptor modulator; vs.=versus

Table 4F.2 Results overview: Hormone therapies versus inactive controls in adults with normal cognition

Author Year Comparison N= Followup | Diagnosis | Biomarkers [specific biomarker] | Brief Cognitive Test Performance/Multidomain Neuropsychological Test Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
HRT-Estrogen Results Summary k=6; n=4,117 | 1 of 3 favors C k=1 | 1 of 7 favors C k=1 | BCT 1 of 2 favors C k=2 MNP 0 of 1 (no difference) k=1 | 2 of 19 favors I k=6 | 2 of 35 favors I k=6 | 4 of 64 favors I 2 of 64 favors C
Henderson, 2016^160^ Oral estrogen therapy (17-beta estradiol 1 mg) daily n=567 2.5 years (5 year outcomes = High ROB) | | | MNP NS [Global Cognition Composite] | NS [Executive Function Composite] | NS [Verbal Episodic Memory Composite] | 0 of 3 (no difference) | 1 death in estradiol group; other serious AEs equal between groups but not included in article
Wroolie, 2015^183^ Continued estrogen-based hormone therapy n=64 2 years | | | | I>C [Attention/Working Memory/Processing Speed Composite] | I>C [Verbal Memory Composite] | 2 of 5 favor I | NR
Wroolie, 2015^183^ Continued estrogen-based hormone therapy n=64 2 years | | | | NS [Executive Function Composite] | NS [Visual Memory Composite]
Wroolie, 2015^183^ Continued estrogen-based hormone therapy n=64 2 years | | | | | NS [Subjective Memory Composite]
Women’s Health Initiative (WHI) substudies Coker, 2009 Resnick, 2009a Resnick, 2009b Espeland, 2004 Shumaker, 2004 Rapp, 2003^149, 151, 175, 177, 178, 180^ Estrogen (conjugated equine estrogen 0.625 mg) daily n=2,947 Mean followup varies by outcome up to 8 years | NS [Probable Dementia] n=2,947 | NS [MRI: Total Brain Volume] n=520 | BCT C>I [3MS] N=2,947 | NS [Letter Fluency] n=886 | NS [BVRT Errors] n=886 | 2 of 16 favors C | Increased risk of probable dementia in women taking estrogen.
| NS [MCI] n=2,947 | NS [MRI: Ventricle Volume] n=520 | | NS [DS Forward] n=886 | NS [CLVT Total List A Trials] n=886 | | Increased risk of global cognitive
| C>I [Probable Dementia or MCI] n=2,947 | NS [MRI: Hippocampal Volume] n=520 | | NS [DS Backward] n=886 | NS [CVLT Total List B] n=886 | | decline in women taking estrogen.
| | C>I [MRI: Frontal Lobe Volume] n=520 | | | NS [CVLT Short Delay Free] n=886
| | NS [White & Gray Matter] n=520 | | | NS [CVLT Long Delay Free] n=886
| | NS [Basal Ganglia] n=520
| | NS [Total Brain Lesion Volume] n=520
Gorenstein, 2011^157^ Estrogen (conjugated equine estrogen 0.625 mg) daily n=65 6 months | | | | I>C [DS Forward] | I>C [PAL, Easy] | 2 of 10 favor I | No serious AEs reported
Gorenstein, 2011^157^ Estrogen (conjugated equine estrogen 0.625 mg) daily n=65 6 months | | | | NS [DS Backward] | NS [PAL, Difficult]
Gorenstein, 2011^157^ Estrogen (conjugated equine estrogen 0.625 mg) daily n=65 6 months | | | | NS [3-min Reasoning Test, Correct] | NS [Immediate Verbal Recall]
Gorenstein, 2011^157^ Estrogen (conjugated equine estrogen 0.625 mg) daily n=65 6 months | | | | NS [3-min Reasoning Test, Time] | NS [Delayed Verbal Recall]
Gorenstein, 2011^157^ Estrogen (conjugated equine estrogen 0.625 mg) daily n=65 6 months | | | | NS [DSST] | NS [Free Recall of Words]
Pefanco 2007^174^ Estrogen (micronized 17-beta estradiol 0.25 mg) daily n=57 3 years | | | | NS [COWAT] | NS [Immediate Recall] | 0 of 22 (no difference) | NR
Pefanco 2007^174^ Estrogen (micronized 17-beta estradiol 0.25 mg) daily n=57 3 years | | | | NS [Animal Naming] | NS [Delayed Recall]
Pefanco 2007^174^ Estrogen (micronized 17-beta estradiol 0.25 mg) daily n=57 3 years | | | | NS [TMT A] | NS [Fuld Object Memory Evaluation]
Pefanco 2007^174^ Estrogen (micronized 17-beta estradiol 0.25 mg) daily n=57 3 years | | | | NS [TMT B] | NS [Total Recall Trial 5]
Pefanco 2007^174^ Estrogen (micronized 17-beta estradiol 0.25 mg) daily n=57 3 years | | | | NS [Wisconsin Test] | NS [Total Recall, 5-Minute Delay]
Pefanco 2007^174^ Estrogen (micronized 17-beta estradiol 0.25 mg) daily n=57 3 years | | | | NS [Total Perservative Error] | NS [Total Recognized 5-Delay]
Pefanco 2007^174^ Estrogen (micronized 17-beta estradiol 0.25 mg) daily n=57 3 years | | | | NS [Digital Written Score] | NS [Wechsler Logical Memory 1]
Pefanco 2007^174^ Estrogen (micronized 17-beta estradiol 0.25 mg) daily n=57 3 years | | | | | NS [Verbal Paired Association 1]
Pefanco 2007^174^ Estrogen (micronized 17-beta estradiol 0.25 mg) daily n=57 3 years | | | | | NS [Visual Representation 1]
Pefanco 2007^174^ Estrogen (micronized 17-beta estradiol 0.25 mg) daily n=57 3 years | | | | | NS [Logical Memory 2]
Pefanco 2007^174^ Estrogen (micronized 17-beta estradiol 0.25 mg) daily n=57 3 years | | | | | NS [Verbal Paired Association 2]
Pefanco 2007^174^ Estrogen (micronized 17-beta estradiol 0.25 mg) daily n=57 3 years | | | | | NS [Visual Representation]
Pefanco 2007^174^ Estrogen (micronized 17-beta estradiol 0.25 mg) daily n=57 3 years | | | | | NS [Recognition Total Score 1]
Pefanco 2007^174^ Estrogen (micronized 17-beta estradiol 0.25 mg) daily n=57 3 years | | | | | NS [Recognition Total Score 2]
Pefanco 2007^174^ Estrogen (micronized 17-beta estradiol 0.25 mg) daily n=57 3 years | | | | | NS [Recognition Total Score 3]
Yaffe, 2006^186^ Estrogen (transdermal patch delivering 0.014 mg estradiol) daily n=417 2 years | | | BCT NS [3MS] | NS [TMT B] | NS [Logical Memory, Immediate] | 0 of 8 (no difference) | NR
Yaffe, 2006^186^ Estrogen (transdermal patch delivering 0.014 mg estradiol) daily n=417 2 years | | | | | NS [Logical Memory, Delayed]
Yaffe, 2006^186^ Estrogen (transdermal patch delivering 0.014 mg estradiol) daily n=417 2 years | | | | | NS [BVMT, Immediate]
Yaffe, 2006^186^ Estrogen (transdermal patch delivering 0.014 mg estradiol) daily n=417 2 years | | | | | NS [BVMTt, Delayed]
Yaffe, 2006^186^ Estrogen (transdermal patch delivering 0.014 mg estradiol) daily n=417 2 years | | | | | NS [Word List, Memory]
Yaffe, 2006^186^ Estrogen (transdermal patch delivering 0.014 mg estradiol) daily n=417 2 years | | | | | NS [Word List, Recall]
HRT-Estrogen + Progestin Results Summary k=5, n=6,332 | 1 of 3 favors C k=1 | 0 of 7 (no differences) k=1 | BCT 1 of 4 favors C k=3 | 1 of 9 favors C k=4 | 4 of 16 favor C k=5 | 6 of 36 favors C
Gleason, 2015^156^ Estrogen + (conjugated equine estrogen 0.45 mg) + progestin (cyclical micronized progesterone 200mg) daily n=482 (o-CEE + placebo) Mean 3.2 years | | | BCT NS [3MS] | NS [Visual Attention & Executive Function Composite] | NS [Verbal Learning & Memory Composite] | 0 of 4 (no difference) | 4 cases of breast cancer 3 in CEE group, 1 in placebo; 2 cardiac or cerebrovascular events – 1 placebo, 1 CEE, 2 cases
Gleason, 2015^156^ Estrogen + (conjugated equine estrogen 0.45 mg) + progestin (cyclical micronized progesterone 200mg) daily n=482 (o-CEE + placebo) Mean 3.2 years | | | | | NS [Auditory Attention & Working memory Composite] | | of major depression, CEE group
Gleason, 2015^156^ Estrogen (transdermal estradiol 200 mg) daily + progestin (cyclical micronized progesterone 200 mg) daily n=431 (t-E2 + placebo) Mean 3.2 years | | | BCT NS [3MS] | NS [Visual Attention & Executive Function Composite] | NS [Verbal Learning & Memory Composite] | 0 of 4 (no difference) | 3 cases of breast cancer (2 estradiol, 1 placebo), 1 stroke, 2 cases
Gleason, 2015^156^ Estrogen (transdermal estradiol 200 mg) daily + progestin (cyclical micronized progesterone 200 mg) daily n=431 (t-E2 + placebo) Mean 3.2 years | | | | | NS [Auditory Attention & Working Memory Composite] | | of venous thrombotic disease (1 estradiol, 1 placebo)
Women’s Health Initiative (WHI) Coker, 2009 Resnick, 2009a Resnick, 2009b Espeland, 2004 Shumaker, 2004 Rapp, 2003^180,149, 151, 175, 177, 178, 189^ Estrogen + progestin daily n=4,532 Mean followup varies by outcome up to 8 years | C>I [Probable Dementia] n=4,532 | NS [MRI: Total Brain Volume] n=883 | BCT C>I [3MS] n=4,532 | NS [Letter Fluency] n=1,416 | C>I [BVRT Errors] n=1,416 | 5 of 16 favor C | In addition to increased risk of probable dementia and
| NS [MCI] n=4,532 | NS [MRI: Ventricle Volume] n=883 | | NS [DS Forward] n=1,416 | C>I [CLVT Total List A Trials] n=1,416 | | memory decline, women taking
| NS [Probable Dementia or MCI] n=4,532 | NS [MRI: Hippocampal Volume] n=883 | | NS [DS Backward] n=1,416 | NS [CVLT Total List B] n=1,416 | | estrogen + progestin experienced more strokes
| | NS [MRI: Frontal Lobe Volume] n=883 | | | C>I [CVLT Short Delay Free] n=1,416 | | than women taking placebo
| | NS [White and Gray Matter] n=883 | | | C>I [CVLT Long Delay Free] n=1,416
| | NS [Basal Ganglia] n=883
| | NS [Total Brain Lesion Volume] n=883
Davison, 2013^150^ Estrogen (oral estradiol + progestin (drospirenone) n=23 (n=13 fMRI) 6 months | | | | NS [CogState Identification] | NS [CogState International Shopping List, Learn] | 1 of 8 favors C | 3 women withdrew from study due to vaginal bleeding: 2 in
Davison, 2013^150^ Estrogen (oral estradiol + progestin (drospirenone) n=23 (n=13 fMRI) 6 months | | | | C>I [CogState, Detection Speed] | NS [CogState International Shopping List, Recall] | | estrogen + progestin group and 1 in placebo.
Davison, 2013^150^ Estrogen (oral estradiol + progestin (drospirenone) n=23 (n=13 fMRI) 6 months | | | | NS [Mental Rotation with functional MRI] | NS [Gorton Maze Learning Task] | | No serious AEs were reported.
Davison, 2013^150^ Estrogen (oral estradiol + progestin (drospirenone) n=23 (n=13 fMRI) 6 months | | | | | NS [Gorton Maze Learning Task, Recall]
Davison, 2013^150^ Estrogen (oral estradiol + progestin (drospirenone) n=23 (n=13 fMRI) 6 months | | | | | NS [CogState Continuous Paired Assoc Learning]
Tierney, 2009^181^ Estrogen (1 mg 17-B estradiol) daily + progestin (0.35 mg norethindrone) 3 times weekly n=142 2 years | | | | | NS CVLT, Short Delay Recall] | 0 of 1 (no difference) | Several serious AEs were reported, including deep vein thrombosis, episodes of heart failure, and stroke. Statistically significant differences between hormone and placebo group were less serious.
Grady, 2002^158^ Conjugated estrogen 0.625 mg) plus medroxyprogerstone acetate (2.5 mg) daily n=1,063 Mean 4.2 years | | | BCT NS [MMSE] | NS [TMT B] | NS [Word List Recall] | 0 of 3 (no difference)
Grady, 2002^158^ Conjugated estrogen 0.625 mg) plus medroxyprogerstone acetate (2.5 mg) daily n=1,063 Mean 4.2 years
DHEA Results Summary k=1, n=225 | NR | NR | BCT 0 of 1 (no difference) k=1 | 0 of 1 (no difference) k=1 | 0 of 2 (no difference) k=1 | 0 of 4 (no difference)
Kritz-Silverstein, 2008^168^ Oral DHEA 50 mg daily n=225 1 year | | | BCT NS [MMSE] | NS [TMT B] | NS [Word List Memory] | 0 of 4 (no difference) | 23 participants experienced AEs,
Kritz-Silverstein, 2008^168^ Oral DHEA 50 mg daily n=225 1 year | | | | | NS [Word List Recall] | | but no tests of significance are reported
SERM Results Summary k=2, n=7,621 | 1 of 8 favors I k=1 | NR | NR | 0 of 6 (no difference) k=2 | 0 of 9 (no difference) k=2 | 0 of 15 (no difference) | NR
Yaffe, 2005^184^ Yaffe, 2001^185^ Raloxifene 60 mg or 120 mg daily vs. placebo n=7,478 years | NS (60 mg group) [MCI] I>C (120 mg group) [MCI] | | | NS [Short Blessed] n=5,734 | NS [Word List Recall] n=5,596 | 0 of 5 (no difference) | NR
Yaffe, 2005^184^ Yaffe, 2001^185^ Raloxifene 60 mg or 120 mg daily vs. placebo n=7,478 years | NS (60 mg group) NS (120 mg group) [CATD] | | | NS [TMT A] n=5,685 | NS [Word List Memory] n=3,607
Yaffe, 2005^184^ Yaffe, 2001^185^ Raloxifene 60 mg or 120 mg daily vs. placebo n=7,478 years | NS (60 mg group) NS (120 mg group) [Any Type of Dementia] | | | NS [TMT B] n=5,538
Yaffe, 2005^184^ Yaffe, 2001^185^ Raloxifene 60 mg or 120 mg daily vs. placebo n=7,478 years | NS (60 mg group) NS (120 mg group) [Dementia or MCI]
Nickelsen, 1999^172^ Raloxifene 60 mg or 120 mg daily vs. placebo n=143 1 year | | | | NS [WRPAB 2-Letter Search] | NS [MAC Battery: Name-Face Association, Total Acquisition] | 0 of 10 (no difference) | No serious AEs reported and % of women with-
Nickelsen, 1999^172^ Raloxifene 60 mg or 120 mg daily vs. placebo n=143 1 year | | | | NS [WRPAB 6-Letter Search] | NS [MAC Battery: Name-Face Association, Delayed Recall] | | drawing from the study due to AEs was
Nickelsen, 1999^172^ Raloxifene 60 mg or 120 mg daily vs. placebo n=143 1 year | | | | NS [WRPAB 4-Choice Serial RT] | NS [MAC Battery: First-Last Name Association, Delayed Recall] | | similar across groups
Nickelsen, 1999^172^ Raloxifene 60 mg or 120 mg daily vs. placebo n=143 1 year | | | | | NS [MAC Battery: First-Last Name Association, Total Acquisition]
Nickelsen, 1999^172^ Raloxifene 60 mg or 120 mg daily vs. placebo n=143 1 year | | | | | NS [MAC Battery: Facial Recognition, Number Before 1st Error]
Nickelsen, 1999^172^ Raloxifene 60 mg or 120 mg daily vs. placebo n=143 1 year | | | | | NS [MAC Battery: Telephone Number Recall, Before Interference]
Nickelsen, 1999^172^ Raloxifene 60 mg or 120 mg daily vs. placebo n=143 1 year | | | | | NS [MAC Battery: Telephone Number Recall, After Interference]
Soy Results Summary k=5; n=829 | NR | NR | BCT 0 of 2 (no difference) k=2 MNP 0 of 3 (no difference) k=2 | 2 of 21 favor C k=5 | 5 of 31 favor I 1 of 31 favors C k=5 | 5 of 57 favor I 3 of 57 favor C
Henderson, 2012^159^ Soy isoflavone rich soy protein 25 g daily vs. matched placebo n=350 2.5 years | | | MNP NS [Composite, components not described] | NS [SDMT] | NS [Verbal Episodic Memory, List Learning Factor: CVLT Immediate & Delayed Recall] | 1 of 15 favors I | 1 person (soy group) had a stroke and 5 people (placebo) reported cancer.
Henderson, 2012^159^ Soy isoflavone rich soy protein 25 g daily vs. matched placebo n=350 2.5 years | | | MNP NS [Executive/Expressive/Visuospatial Factor Composite: SDMT, TMT B, Shipley Abstraction, Letter-Number Sequencing, Block Design, Judgment of Line Orientation, BNT] | NS [TMT B] | NS [CVLT, Immediate Recall] | | No other serious adverse effects were reported.
Henderson, 2012^159^ Soy isoflavone rich soy protein 25 g daily vs. matched placebo n=350 2.5 years | | | | NS [Shipley Abstraction] | NS [CVLT, Delayed Recall]
Henderson, 2012^159^ Soy isoflavone rich soy protein 25 g daily vs. matched placebo n=350 2.5 years | | | | NS [Letter-Number Sequencing] | NS [Verbal Episodic Memory, Logical Memory Factor: EBMT, Immediate & Delayed Recall]
Henderson, 2012^159^ Soy isoflavone rich soy protein 25 g daily vs. matched placebo n=350 2.5 years | | | | | NS [EBMT, Immediate Recall]
Henderson, 2012^159^ Soy isoflavone rich soy protein 25 g daily vs. matched placebo n=350 2.5 years | | | | | NS [EBMT, Delayed Recall]
Henderson, 2012^159^ Soy isoflavone rich soy protein 25 g daily vs. matched placebo n=350 2.5 years | | | | | I>C [Visual Episodic Memory Factor: Faces I, Faces II]
Henderson, 2012^159^ Soy isoflavone rich soy protein 25 g daily vs. matched placebo n=350 2.5 years | | | | | NS [Faces I]
Henderson, 2012^159^ Soy isoflavone rich soy protein 25 g daily vs. matched placebo n=350 2.5 years | | | | | NS [Faces II]
Gleason, 2009^155^ Soy isoflavonea 100 mg daily vs. placebo n=30 6 months | | | | C>I [SCWT] | NS [Buschke Selective Reminding Test, Total of Learning Trials – Words] | 4 of 14 favor I | NR
Gleason, 2009^155^ Soy isoflavonea 100 mg daily vs. placebo n=30 6 months | | | | C>I [TMT B] | NS [Buschke Selective Reminding Test, Learning Slope, Trial 5 vs. Trial 1] | 3 of 14 favor C
Gleason, 2009^155^ Soy isoflavonea 100 mg daily vs. placebo n=30 6 months | | | | NS [Mazes] | NS [Delayed Recall, Words]
Gleason, 2009^155^ Soy isoflavonea 100 mg daily vs. placebo n=30 6 months | | | | NS [Language Fluency, Letter] | NS [Paragraph Recall Test, Total Immediate Recall]
Gleason, 2009^155^ Soy isoflavonea 100 mg daily vs. placebo n=30 6 months | | | | | NS [Paragraph Recall Test, Total Delayed Recall]
Gleason, 2009^155^ Soy isoflavonea 100 mg daily vs. placebo n=30 6 months | | | | | I>C [RCFT, Immediate Recall]
Gleason, 2009^155^ Soy isoflavonea 100 mg daily vs. placebo n=30 6 months | | | | | I>C [RCFT, Delayed Recall]
Gleason, 2009^155^ Soy isoflavonea 100 mg daily vs. placebo n=30 6 months | | | | | C>I [Visual Spatial Learning Test, Total Correct Position + Designs]
Gleason, 2009^155^ Soy isoflavonea 100 mg daily vs. placebo n=30 6 months | | | | | I>C [Visual Spatial Learning Test, Learning Slope Position + Design, Trial 5 vs. Trial 1]
Gleason, 2009^155^ Soy isoflavonea 100 mg daily vs. placebo n=30 6 months | | | | | I>C [Visual Spatial Learning Test, Learning Slope Incorrect Designs]
Ho, 2007^161^ Soy-derived isoflavones 80 mg vs. placebo n=191 6 months | | | BCT NS [MMSE] | NS [Color Trail I] | NS [HKLLT, Trials 1–5] | 0 of 11 (no difference) | No significant differences in AEs experienced
Ho, 2007^161^ Soy-derived isoflavones 80 mg vs. placebo n=191 6 months | | | MNP NS [Cognitive Score=z scores of all cognitive tests] | NS [Color Trail II] | NS [HKLLT, Short Delay Recall] | | or their severity were found between groups.
Ho, 2007^161^ Soy-derived isoflavones 80 mg vs. placebo n=191 6 months | | | | NS [DSST – WAIS] | NS [HKLLT, Long Delay Recall] | | No serious AEs were reported.
Ho, 2007^161^ Soy-derived isoflavones 80 mg vs. placebo n=191 6 months | | | | | NS [VR I]
Ho, 2007^161^ Soy-derived isoflavones 80 mg vs. placebo n=191 6 months | | | | | NS [VR II]
Ho, 2007^161^ Soy-derived isoflavones 80 mg vs. placebo n=191 6 months | | | | | NS [VR, Copy]
Kreijkamp-Kaspers, 2004{Kreijkamp-Kaspers, 2004) Soy-derived isoflavones 99 mg vs. placebo n=202 1 year | | | BCT NS [MMSE] | NS [DS Forward] | NS [RAVLT, Immediate Recall] | 0 of 13 (no difference) | No serious AEs reported and no significant
Kreijkamp-Kaspers, 2004{Kreijkamp-Kaspers, 2004) Soy-derived isoflavones 99 mg vs. placebo n=202 1 year | | | | NS [DS Backward] | NS [RAVLT, Delayed Recall] | | differences between groups were
Kreijkamp-Kaspers, 2004{Kreijkamp-Kaspers, 2004) Soy-derived isoflavones 99 mg vs. placebo n=202 1 year | | | | NS [TMT A1] | NS [RAVLT, Recognition] | | found.
Kreijkamp-Kaspers, 2004{Kreijkamp-Kaspers, 2004) Soy-derived isoflavones 99 mg vs. placebo n=202 1 year | | | | NS [TMT A2] | NS [Doors Test]
Kreijkamp-Kaspers, 2004{Kreijkamp-Kaspers, 2004) Soy-derived isoflavones 99 mg vs. placebo n=202 1 year | | | | NS [TMT B]
Kreijkamp-Kaspers, 2004{Kreijkamp-Kaspers, 2004) Soy-derived isoflavones 99 mg vs. placebo n=202 1 year | | | | NS [DSST]
Kreijkamp-Kaspers, 2004{Kreijkamp-Kaspers, 2004) Soy-derived isoflavones 99 mg vs. placebo n=202 1 year | | | | NS [Verbal Fluency, N]
Kreijkamp-Kaspers, 2004{Kreijkamp-Kaspers, 2004) Soy-derived isoflavones 99 mg vs. placebo n=202 1 year | | | | NS [Verbal Fluency, A]
Kritz-Silverstein, 2003^167^ Soy-extracted isoflavones 110 mg daily vs. placebo n=56 6 months | | | | NS [TMT A] | NS [Logical Memory I, Immediate] | 0 of 4 (no difference) | NR
Kritz-Silverstein, 2003^167^ Soy-extracted isoflavones 110 mg daily vs. placebo n=56 6 months | | | | NS [TMT B] | NS [Logical Memory II, Delayed]
Red Clover Results Summary k=1; n=30 | NR | NR | NR | 1 of 5 favors I k=1 | 2 of 7 favor C k=1 | 1 of 12 favors I 2 of 12 favor C
Howes, 2004^162^ Isoflavones from red clover n=30 6 months | | | | NS [Arithmetic Test] | C>I [Digit Recall Test] | 1 of 12 favors I 2 of 12 favor C | 1 person receiving placebo died. No other serious
Howes, 2004^162^ Isoflavones from red clover n=30 6 months | | | | NS [TMT A] | NS [Memory 1 Test] | | AEs were reported.
Howes, 2004^162^ Isoflavones from red clover n=30 6 months | | | | NS [TMT B] | NS [Memory 2 Test]
Howes, 2004^162^ Isoflavones from red clover n=30 6 months | | | | I>C [Block Design Test] | NS [Verbal Memory 1 Test]
Howes, 2004^162^ Isoflavones from red clover n=30 6 months | | | | NS [DSST] | C>I [Verbal Memory 2 Test]
Howes, 2004^162^ Isoflavones from red clover n=30 6 months | | | | | NS [Visual Memory 1 Test]
Howes, 2004^162^ Isoflavones from red clover n=30 6 months | | | | | NS [Visual Memory 2 Test]

3MS=Modified Mini-Mental State Examination; AE=adverse effect; BCT=brief cognitive test performance; BNT=Boston Naming Test; BVMT=Brief Visuospatial Memory Test; BVRT=Benton Visual Retention Test; C=control; CATD=clinical Alzheimer’s-type dementia; COWAT=Controlled Oral Word Association Test; CVLT=California Verbal Learning Test; DHEA=dehydroepiandrosterone; DS=Digit Span (Forward and/or Backward); DSST=Digit Symbol Substitution Test; EBMT=East Boston Memory Test; fMRI=functional magnetic resonance imaging; HKLLT=Hong Kong List Learning Test; HRT=hormone replacement therapy; I=intervention; k=number of studies included; mg=milligrams; MMSE=Mini-Mental State Examination; MNP=multidomain neuropsychological test performance; MRI=magnetic resonance imaging; n=sample size; NS=no statistically significant difference; NR=not reported; PAL=Paired Associated Learning Test; RAVLT=Rey Auditory Verbal Learning Test; RCFT=Rey-Osterrieth Complex Figure Test; SCWT=Stroop Color Word Test; SERM=selective estrogen receptor modulator; TMT=Trail Making Test (Part A and/or B)

Shading indicates summary rows and columns.

### Efficacy: Hormone Therapy Versus Inactive Control

Nineteen randomized controlled trials (RCTs) with low to medium risk of bias enrolling a total of 19,154 adults compared hormone therapy interventions to inactive controls in adults with normal cognition.^150, 151, 153–163, 166–168, 172, 174, 175, 177–181, 183–186, 189^ Interventions included hormone replacement therapies: estrogen only, combined estrogen and progestin, dehydroepiandrosterone (DHEA), and testosterone; SERM; soy; and red clover. Samples ranged from 23 to 7,478 participants, with followup duration of 6 months to over 5 years.

#### Hormone Replacement Therapies

Hormone replacement therapies included estrogen-only therapy, estrogen plus progestin, DHEA, and testosterone. The two testosterone studies were assessed as high risk of bias due to attrition. Enrollment criteria differed among trials, with most studies focusing on older women. The estrogen-only and combined estrogen-progestin trials enrolled premenopausal and postmenopausal women aged 40 to 91 years with normal to “mildly impaired memory functioning”^181^ at baseline. The study on DHEA included healthy men and women aged 55 to 85 years, and the studies of testosterone included men aged 65 to 87 years.

##### Estrogen Only

Six RCTs (n=4,117) with low to medium risk of bias compared estrogen replacement therapy to placebo in healthy postmenopausal women.^149, 151–153, 157, 160, 174, 175, 177, 178, 180, 183, 186^ Studies included several small to moderately-sized RCTs (n=57–567 participants) and two ancillary studies of the large longitudinal WHI (n=2,947, estrogen-only arm), the Women’s Health Initiative Memory Study (WHIMS) and Women’s Health Initiative Study of Cognitive Aging (WHISCA). Study durations ranged from 6 months to over 5 years.

The WHIMS reported diagnostic outcomes (n=2,947).^180^ After a mean followup of 7 years, women taking estrogen were significantly more likely to experience probable dementia or MCI when the two diagnostic categories were combined. Although an increase in probable dementia or MCI diagnosis was also observed for women taking estrogen when the diagnostic categories were examined separately, the results did not reach statistical significance. Evidence is low strength that estrogen-only therapy increases the combined risk of probable dementia/MCI given medium study limitations and unknown consistency.

WHIMS participants (520 women aged 71–89 years) were tested for total ischemic lesion volume^149^ and changes in brain volume.^178^ No differences were found between estrogen and placebo groups in brain lesions. Of four measures of brain volume, women receiving estrogen therapy experienced statistically greater brain atrophy in frontal lobe volume.

Two studies (n=3,364), the WHIMS and Yaffe et al., used the 3MS as a brief test of cognitive performance.^151, 186^ The dose of estrogen used in Yaffe et al.’s study was very low, only 0.014 mg daily (compared to 0.625 mg daily in WHIMS). Yaffe et al. found no statistically significant differences between estrogen and placebo groups after two years. After a mean followup of 5.4 years in the WHIMS, however, women taking estrogen performed slightly worse on the Modified Mini-Mental State Examination (3MS) than women taking placebo (difference in mean change from baseline: −0.26, 95% CI: −0.52, 0). Evidence was rated low that higher dose estrogen is associated with decreased performance on the 3MS compared to placebo.

Henderson et al.^160^ (n=567) assessed cognition using a multi-domain composite. No difference was found between estrogen and placebo groups. Evidence was rated insufficient.

All six studies (n=2,056) examined changes in cognitive performance related to executive function/attention/processing speed and memory. (A sub-set of 886 WHISCA participants contributed to these outcomes.)^177^ Two of 19 tests of executive function, attention, and processing speed favored estrogen, with none of the tests favoring placebo. Similarly, of 35 tests of memory across the studies, two favored estrogen and none favored placebo. Evidence was rated low that estrogen provides no benefit to executive function/attention/processing speed or memory over placebo.

Henderson et al. found no difference in outcomes between women nearer to and further from menopause.^160^ WHIMS investigators conducted subgroup analyses to examine the effects of baseline risk factors on 3MS scores.^151^ Analyses examining the effects of age, education, race/ethnicity, annual household income, Body Mass Index (BMI), smoking status, alcohol consumption, prior cardiovascular disease, treatment for hypertension, diabetes mellitus, presence of moderate or severe vasomotor symptoms, prior hormone therapy use, age at hysterectomy, prior bilateral oophorectomy, prior use of HMG-CoA reductase inhibitors, baseline aspirin use, and baseline 3MS scores on changes in 3MS scores found statistically significant effects based on age, moderate or severe vasomotor symptoms, and baseline 3MS scores.^151^

Henderson et al.^160^ (n=567) reported similar rates of serious adverse effects across estrogen and placebo groups. Gorenstein et al. reported no serious adverse effects associated with estrogen therapy and noted that study withdrawals due to adverse effects were similar across estrogen and placebo groups.^157^ In the WHIMS, women taking estrogen experienced a higher risk of stroke in addition to a higher risk of probable CATD/MCI than women taking placebo.^180^

##### Estrogen Plus Progestin

Five RCTs with low to medium risk of bias ranging in size from 23 to 4,532 participants (total n=6,332) compared combination estrogen/progestin therapy with placebo in postmenopausal women. Studies included three small RCTs^150, 158, 181^, the Kronos Early Estrogen Prevention Study-Cognitive and Affective Study (KEEPS-Cog) (n=505)^156^ and the WHIMS and WHISCA substudies of the WHI.^149, 175, 178, 179, 189^ Specific estrogen/progestin combination therapies varied across studies.

The WHIMS was the only study to report diagnostic outcomes (n=4,532).^179^ Of three diagnostic categories, including probable dementia, MCI, or probable dementia/MCI combined, only the probable dementia category showed statistically significant differences between estrogen/progestin and placebo groups, with women receiving estrogen/progestin experiencing higher rates of probable CATD. Evidence was rated low that estrogen-progestin increases the risk of probable CATD.

WHIMS participants (a subset of 883 women aged 71–89 years at the time of MRI scans) were tested for total ischemic lesion volume^149^ and changes in brain volume.^178^ No differences in brain lesions or brain volume were found between estrogen/progestin and placebo groups.

Three studies (n=6,100) used the 3MS as a brief cognitive test.^156, 158, 175^ Only the WHIMS found a statistically significant difference between estrogen/progestin and placebo groups, favoring the controls. Although performance on the 3MS improved over time for both WHIMS groups, the improvement was more marked for women taking placebo.^175^ Evidence was rated low.

Four studies (n=3,007) examined the effect of estrogen/progestin therapy versus placebo on cognition in the executive function/attention/processing speed domain.^150, 177^ One of nine tests of executive/attention/processing speed favored placebo. Evidence was low-strength that combined estrogen/progestin therapy has no effect on this domain.

All five studies (n=3,149) tested the effects of estrogen/progestin on memory.^156, 158, 175, 181^ Four of 16 memory tests favored placebo and no tests favored estrogen/progestin. Evidence was rated low that combined estrogen/progestin therapy negatively affects memory compared to placebo.

Several subgroup analyses were conducted. Tierney found that women in the estrogen/progestin group who scored at or above average at baseline on short-delay recall showed significantly less decline than the placebo group after 1 year, although this same result was not observed at year 2.^181^ No treatment effects were found for women who scored below average on short-delay recall, nor for women in the estrogen-progestin group compared to placebo overall.

In the WHIMS, subgroup analyses examined the relationship between baseline risk factors and 3MS scores by treatment group.^151^ Of covariates including age, education, race/ethnicity, annual household income, BMI, smoking status, alcohol consumption, prior cardiovascular disease, treatment for hypertension, diabetes mellitus, presence of moderate or severe vasomotor symptoms, prior hormone therapy use, age at hysterectomy, prior bilateral oophorectomy, prior use of HMG-CoA reductase inhibitors, baseline aspirin use, and baseline 3MS scores statistically significant effects were found only for baseline 3MS scores.^151^ Also in the WHIMS,^179^ no interaction was found between treatment assignment (estrogen/progestin or placebo) on rates of probable dementia diagnoses for 10 subgroups of women based on age, education, history of stroke, history of diabetes, prior hormone therapy, prior use of estrogen therapy, prior use of estrogen/progestin therapy, prior use of statins, prior use of aspirin, and baseline 3MS score.

Women taking estrogen/progestin in WHIMS experienced increased risk of probable CATD, as well as an increased risk of stroke.^149, 179^ Tierney et al. reported death (two in hormone group and two in placebo group), deep vein thrombosis (DVT) (one participant in hormone group with a history of DVT), symptoms of heart failure (three women in hormone group, one of whom withdrew from study), colorectal cancer (one participant) and silent stroke (five participants in hormone group and four in placebo).^181^ The reported deaths, silent strokes, and cancer were deemed by study physicians to be unrelated to hormone therapy. Other less serious adverse effects, which were experienced significantly more frequently by women taking hormones, included breast tenderness, vaginal bleeding and discharge, and gastrointestinal problems. In Davison et al., three women discontinued from the study due to vaginal bleeding, including one women in the hormone group and two taking placebo.^150^

##### DHEA

One RCT (n=225) compared daily oral DHEA (50mg) to placebo in women and men aged 55 to 85 years with a mean baseline 3MS score of 96.^168^ Cognitive outcomes included three measures: a brief cognitive test (the 3MS), a test of executive function, and a test of verbal memory. After 1 year of treatment, no differences were found between DHEA and placebo groups in cognitive function. A total of 33 participants withdrew from the trial due to serious side effects, including 23 people receiving DHEA (67% of withdrawals) and 10 receiving placebo. Serious side effects included chest pain, heart palpitations, and an increase in prostate-specific antigen (PSA) in men. No sub-analyses were reported. Strength of evidence was insufficient due to limited data (single study with n<500).

##### Testosterone

Two high risk of bias RCTs (n=136) with primary outcomes related to the effects of testosterone on bone density^165, 182^ and muscle^165^ in older men with low bioavailable testosterone levels examined the effect of testosterone on cognitive performance.

##### Selective Estrogen Receptor Modulators (SERM)

Two trials (n=7,621) compared the SERM raloxifene (60 mg or 120 mg daily in both trials) with placebo.^172, 184^ Both studies enrolled women with osteoporosis aged 66 to 68 years.

Yaffe et al.’s 3-year study (n=7,478) reported diagnostic outcomes.^184^ At year 3, women who scored in the bottom 10 percent of cognitive scores or who had symptoms of cognitive impairment were referred for further evaluation. Evaluation for MCI or CATD involved interview, physical, and neurological examination by a clinician who was blinded to treatment, as well as administration of several cognitive tests. Participants suspected of having CATD based on clinical assessment and a Mini-Mental State Examination (MMSE) score of < 24 underwent magnetic resonance imaging (MRI) scans, which were subsequently assessed by a blinded reader to determine whether scans were clinically relevant. Women assigned to 120 mg of raloxifene daily had a 33 percent lower risk of MCI than those taking placebo, although the 95 percent confidence interval was 0.46 to 0.98. The same effect was not observed in women taking the lower dose (60 mg) of raloxifene. No statistically significant differences were found between treatment and placebo groups in three other diagnostic categories, including “Alzheimer’s disease,” “any type of dementia,” and “dementia or MCI.” As expected, women found to have MCI or CATD were likely to be older, less educated, more depressed, and further past menopause than women with normal cognition. Evidence was low that raloxifene lowers the risk of MCI.

Both Nickelsen et al. and Yaffe et al. (n=5,877) compared the effects of raloxifene and placebo on executive/attention/processing speed and memory.^172, 184, 185^ A total of six cognitive tests related to executive, attention, and processing speed were conducted between the two studies, and a total of nine memory tests. No significant differences were found between raloxifene and placebo groups after 3 years. Strength of evidence was rated low.

No serious adverse effects related to raloxifene were described. In Nickelsen et al.’s study, the percentage of women withdrawing from the study due to adverse effects was similar across treatment and placebo groups.^172^

#### Soy

Five low to medium risk of bias RCTs ranging in size from 34 to 350 participants (total n=829) compared soy supplementation to placebo. Populations included men and women without dementia aged 62 to 89 years^155^ and generally healthy postmenopausal women.^159, 161, 167^ Mean baseline MMSE scores were not reported in Henderson et al.^159^ and Kreijkamp-Kaspers et al.,^166^ but ranged from 28 to 29 in the other studies.^155, 161, 167^ Three of the studies took place over 6 months (n=281),^155, 161, 167^ one lasted 1 year (n=202), and one lasted 2.5 years (n=350).^159^

None of the trials reported diagnostic outcomes. Ho^161^ (n=191) and Kreijkamp-Kaspers et al.,^166^ (n=202) used the MMSE as a brief cognitive test and found no pre/post differences between soy and placebo groups.^161^ Strength of evidence was insufficient. Two studies (n=541) tested multi-domain neuropsychological performance and found no statistically significant differences between groups.^159, 161^ Evidence was rated as insufficient.

All five studies measured cognitive performance in the executive function/attention/processing speed and memory categories (n=829). Placebo performed better than soy in two of 21 tests of executive function/attention/processing speed. Over the five studies, the soy group performed better on five of 31 memory tests, with the placebo group performing better on one memory test. Evidence is low-strength that soy has no effect on these cognitive domains.

Subanalyses conducted by Kritz-Silverstein et al. found that younger women taking placebo (those aged 50 to 59) improved in verbal memory scores whereas those aged 60 to 74 worsened in verbal memory over time.^167^ Neither Henderson nor Ho found differences in cognitive performance based on age.^159, 161^

Ho et al. and Kreijkamp-Kaspers et al. reported no serious adverse effects and no significant differences in adverse effects experienced between treatment and placebo groups.^161, 166^ In Henderson et al.’s study, one person in the soy group experienced a stroke and five people in the placebo group reported cancer.^159^ No other serious adverse effects were reported.

#### Red Clover

A single study (n=30)^162^ with medium risk of bias compared isoflavone supplementation with red cover to placebo. Red clover performed better than placebo on one of five tests of executive function/attention/processing speed and placebo performed better on two of seven memory tests. However, the study authors note that none of the results remained significant after correcting for multiple comparisons. Strength of evidence was insufficient due to a single study of less than 500 participants.

### Comparative Effectiveness: Hormone Therapies Versus Active Comparison

Two studies (three publications) with low to medium risk of bias compared hormone therapies with active interventions.^170, 171, 173^ Results are summarized in Table 4F.3. Both studies enrolled younger postmenopausal women (mean ages: 43 and 52 years) and assessed changes in cognition after a 6-month treatment period. Neither study reported diagnostic outcomes. Limited data prevented assessment of strength of evidence for other cognitive outcomes.

Table 4F.3 Results overview: Hormone therapy versus active controls in adults with normal cognition

Author Year Comparison N= Followup | Diagnosis | Biomarkers [specific biomarker] | Brief Cognitive Test Performance/Multidomain Neuropsychological Test Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
HRT-Estrogen plus Progestin vs. Tibolone Results Summary k=1; n=50 | NR | NR | BCT 0 of 2 (no difference) k=1 | NR | NR | 0 of 2 (no difference)
Pan, 2003^173^ Estrogen + progestin (CEE 0.625 mg/day + methylprogresterone acetate 5 mg/day) vs. tibolone 2.5 mg/day n=50 6 months | | | BCT NS [MMSE] | | | 0 of 2 (no difference) | AEs reported but differences
Pan, 2003^173^ Estrogen + progestin (CEE 0.625 mg/day + methylprogresterone acetate 5 mg/day) vs. tibolone 2.5 mg/day n=50 6 months | | | BCT NS [CASI] | | | | Not reported in terms of statistical significance.
HRT-Estrogen plus Testosterone vs. Estrogen Results Summary k=1; n=50 | NR | NR | NR | 0 of 4 (no difference) k=1 | 0 of 2 favor I1 (estrogen + testosterone k=1 1 of 2 favors I-2 (estrogen only) k=1 | 0 of 6 favor I_1_ (estrogen + testosterone) 1 of 6 favors I_2_ (estrogen + placebo)
Moller, 2013^171^ Moller, 2010^170^ Estrogen + testosterone (I_1_) versus estrogen + placebo (I_2_) (estradiol valerate 2 mg/day + testosterone undecanoate 40 mg/day versus estradiol valerate 2 mg/day + placebo) n=50 6 months (crossover design; total trial period = 12 months) | | | | NS [DSST – WAIS, used to assess cognitive fatigue]^*1^ | I_1_ < I_2_ [Logical Story, Immediate Recall]^2^ | 0 of 6 favors I_1_ | NR (other than 1 withdrawal due to migraine.
| | | | NS [DSST, Free Recall of Symbols] ^1^ | NS [Logical Story, Delayed Recall]^2^ | 1 of 6 favors I_2_
| | | | NS [DSST, Paired Recall of Symbols] ^1^
| | | | NS [DSST, % Spatial Errors]^2^

* The difference between the # of digits produced during the first 30 seconds and last 30 seconds of a 90 second session]

AE=adverse effect; BCT=brief cognitive test performance; C=control; CASI=Cognitive Abilities Screening Instrument; DSST=Digit Symbol Substitution Test; HRT=hormone replacement therapy; I=intervention; I_1_=first intervention; I_2_=second intervention; k=number of studies included; mg=milligrams; MMSE=Mini-Mental State Examination; n=sample size; NS=no statistically significant difference; NR=not reported

Shading indicates summary rows and columns.

## Adults With MCI

### Efficacy: Hormone Therapies Versus Inactive Control

We identified two RCTs that compared hormone therapies with inactive controls in older adults with MCI.^148, 164^ Results are summarized in Table 4F.4. Cherrier et al. compared the effects of testosterone gel (50–100 mg/day) versus placebo on cognitive performance in men diagnosed with MCI (according to Petersen’s criteria) and low serum testosterone levels.^148^ The study was small (22 men) and conducted over a 6-month period. Of 14 cognitive tests involving memory and executive/attention/processing speed, only one showed a statically significant difference (in a test of verbal memory) between testosterone and placebo groups. Three serious adverse events were reported: one participant visited the emergency department (ED) for chest pains, upper arm pain, and dizziness; a second participant visited the ED for confusion and disorientation; a third participant had a rise in PSA levels and discontinued study medication per study protocol. Evidence was insufficient due to limited data (single study with n<500).

Table 4F.4 Results overview: Hormone therapy versus inactive controls in adults with MCI

Author Year Comparison N= Followup | Diagnosis | Biomarkers [specific biomarker] | Brief Cognitive Test Performance/Multidomain Neuropsychological Test Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
HRT-Testosterone Results Summary k=1; n=22 | NR | NR | NR | 0 of 7 (no difference) k=1 | 1 of 7 favors I k=1 | 1 of 14 favors I
Cherrier, 2015^148^ Testosterone gel 50–100 mg/d with a target total T level of 500 to 900 ng/dL n=22 6 months | | | | NS [Letter-Number Sequencing, Total Score] | NS [RAVLT, Immediate, Total Score, 4 Trials] | 1 of 14 favors I | 3 serious AEs reported (2 in treatment and 1 in placebo
Cherrier, 2015^148^ Testosterone gel 50–100 mg/d with a target total T level of 500 to 900 ng/dL n=22 6 months | | | | NS [Letter-Number Sequencing, Span] | NS [RAVLT, Short Delay] | | group), although no significance tests reported
Cherrier, 2015^148^ Testosterone gel 50–100 mg/d with a target total T level of 500 to 900 ng/dL n=22 6 months | | | | NS [Computerized Simple RT, 2-Second Interval] | I>C [RAVLT, Long Delay]
Cherrier, 2015^148^ Testosterone gel 50–100 mg/d with a target total T level of 500 to 900 ng/dL n=22 6 months | | | | NS [Computerized Simple RT, 5-Second Interval] | NS [Story Recall, Immediate]
Cherrier, 2015^148^ Testosterone gel 50–100 mg/d with a target total T level of 500 to 900 ng/dL n=22 6 months | | | | NS [Computerized Choice RT, 2-Second Interval] | NS [Story Recall, Delay]
Cherrier, 2015^148^ Testosterone gel 50–100 mg/d with a target total T level of 500 to 900 ng/dL n=22 6 months | | | | NS [Computerized Choice R, 5-Second Interval] | NS [Visual Spatial Learning Test, Immediate]
Cherrier, 2015^148^ Testosterone gel 50–100 mg/d with a target total T level of 500 to 900 ng/dL n=22 6 months | | | | NS [Mental Rotation] | NS [Visual Spatial Learning Test, Delay]
Soy Results Summary k=1; n=78 | NR | NR | BCT 1 of 2 favors C (100 mg group) k=1 0 of 2 (no difference) (300 mg group) k=1 | NR | 0 of 1 (no difference) (100 & 300 mg groups) k=1 | 1 of 6 favors I (3 tests, 2 doses) | NR
Kato-Kataoka, 2010^164^ Soybean derived phosphatidylserine (Soy-PS) 100 mg or 300 mg vs. placebo n=78 9 months | | | BCT I>C (100 mg group) [MMSE] BCT NS (300 mg group) [MMSE] | | NS (100 mg group) [RBMT] NS (300 mg group) [RBMT] | 1 of 6 favors I | NR
Kato-Kataoka, 2010^164^ Soybean derived phosphatidylserine (Soy-PS) 100 mg or 300 mg vs. placebo n=78 9 months | | | BCT NS (100 mg group) [Hawegawa Dementia Scale] BCT NS (300 mg group) [Hawegawa Dementia Scale]

AE=adverse effect; BCT=brief cognitive test performance; C=control; HRT=hormone replacement therapy; I=intervention; k=number of studies included; mg=milligrants; mg/d=milligrams per day; MMSE=Mini-Mental Status Examination; n=sample size; ng/dL=nanograms per deciliter; NR=not reported; NS=no statistically significant difference; RAVLT=Rey Auditory Verbal Learning Test; RBMT= Rivermead Behavioral Memory Test; RT=reaction time;

Shading indicates summary rows and columns.

In another study, Kato-Kataoka et al. examined the use of soybean derived phosphatidylserine (soy-PS) at two doses, 100 mg and 300 mg daily, in 78 men and women with MCI and a mean age of 60 (SD: 1 year).^164^ Treatment took place over a 6-month period, with an additional 3 months of followup. Two brief tests of cognitive performance (the MMSE and Hasegawa Dementia Scale) and a memory test were used to assess cognition. Although cognitive scores increased from baseline in all three treatment groups (soy-PS at two doses and placebo), no significant differences were observed between soy and placebo groups at any time point. No adverse effects were reported. Evidence was insufficient due to limited data (single study with n<500).

## Interpreting the Findings

Overall, evidence demonstrating the effect of hormone therapies on cognitive outcomes was deemed to be low or insufficient. While there was more evidence supporting the conclusion that the harms associated with hormone replacement therapies (estrogen and combined estrogen/progestin therapy in particular) may outweigh their benefits, less is known about the effects of other hormone therapies, such as SERM and plant-based estrogens, on cognition. In most cases, differences in cognitive performance between hormone therapy and control groups tended to be relatively small and lacking in clinical significance.

Some of the most compelling evidence against the use of hormone replacement therapy to prevent cognitive decline or dementia arose from the longitudinal WHI, a study well known for the early termination of its estrogen/progestin arm due to associated adverse events—cancer and cardiovascular disease in particular.^190^ Particularly when data for women taking either hormone replacement therapy (estrogen-only or estrogen/progestin) were combined,^180^ the detrimental effects of hormone therapy on cognition (both in terms of dementia-related diagnoses and cognitive performance) became more pronounced. Importantly, the trial found a 76 percent increased hazard for dementia associated with hormone therapy.^180^

Many studies of the effects of hormone therapies on cognition were relatively short, making it difficult to draw conclusions about the long-term effects of hormone therapies on cognition. Further, the considerable variation in cognitive measures across studies further complicates our ability to draw clear conclusions. Of 31 RCTs included in the review, only two included diagnostic outcomes. Both of the studies were ancillary/substudies of larger longitudinal clinical trials and cognitive outcomes were not the studies’ primary outcomes. One of these studies, the WHI, found that hormone replacement therapy (estrogen-only or combined estrogen/progestin therapy) may increase the risk of probable dementia and/or MCI. The other study found that the selective estrogen receptor modulator raloxifene may lower the risk of MCI when compared to placebo. Both of these studies included older, postmenopausal women and less is known about the effects of hormone therapies on cognition in younger women, or on women who begin using hormone therapies at younger ages. Similarly, little is known about the effects of hormone therapies on cognition in men.

Finally, although a number of studies examined the effects of phytoestrogens (soy in particular) on cognition, none of these studies looked at diagnostic outcomes. Low-strength evidence suggests that soy offers no benefit to cognition related to executive/attention/processing speed or memory, yet evidence was deemed insufficient for other cognitive outcomes.

* Note that the literature currently does not use the term CATD; we specified whenever the diagnosis of dementia was defined.