# 4E Results: Multimodal Interventions

## Key Messages

- Evidence is insufficient to conclude whether most multimodal interventions offer benefits for cognitive performance or incidence of mild cognitive impairment (MCI) or clinical Alzheimer’s-type dementia (CATD),^*^ largely because few studies have examined interventions with similar components.
- Low-strength evidence shows that a multimodal intervention composed of diet, physical activity, and cognitive training provides benefits in executive function/attention/processing speed.
- Low-strength evidence shows that a multimodal intervention composed of lifestyle advice and drug treatment is not effective in reducing incidence of CATD or benefiting brief cognitive test performance or memory.

## Eligible Studies

We identified 21 eligible publications that reported unique studies of multimodal interventions to prevent age-related cognitive decline, MCI, or CATD.^62, 66, 69, 72, 83, 87, 97, 126, 132–144^ Thirteen were assessed as high risk of bias and not used in our analysis.^66, 69, 72, 87, 132, 134, 136–140, 143, 144^ We analyzed the efficacy and comparative effectiveness of multimodal interventions separately for adults with normal cognition and those with MCI. Appendix J provides evidence tables, summary risk of bias assessments, and assessments of strength of evidence for key comparisons and outcomes.

## Logic of Multimodal Interventions

Studies that examine multimodal interventions theorize that an integrated approach to addressing multiple risk factors for CATD may be more successful than single component interventions in producing benefits.^62, 133, 142^ Multimodal interventions often include components like physical activity, changes to diet, and cognitive training. Several of the studies included in this review have suggested mechanisms for the relationship between individual components like physical activity^54, 80, 91^ or cognitive training^25^ and reduced dementia risk. Because an almost infinite number of interventions can be combined, creating categories for review and analysis is a daunting task.

Table 4E.1 lists the components included in the seven studies that had low to medium risk of bias. Six of the eight studies included physical activity as part of the multimodal intervention. The two most frequent combinations across the eight studies were physical activity with changes to diet and physical activity with cognitive training. Other components include protein supplementation and goal setting.

Table 4E.1 Components of multimodal interventions for low/medium risk of bias trials

Study | Physical Activity | Diet | Cognitive Training | Protein Supplements | Goal Setting | Lifestyle Advice | Drug Treatment
Clare, 2015^133^ | | | | | •
Eggenberger, 2015^62^ | • | | •
Ngandu, 2015^142^ | • | • | •
Hars, 2014^135^ | • | | •
Napoli, 2014^83^ | • | •
van de Rest, 2014^97^ | • | | | •
Martin, 2007^126^ | • | •
Moll van Charante, 2016 | | | | | | • | •

## Adults With Normal Cognition

### Efficacy: Multimodal Interventions Versus Inactive Control

Seven studies with low to medium risk of bias enrolling a total of 5,132 adults compared multimodal interventions with inactive controls in adults with normal cognition.^83, 97, 126, 133, 135, 141, 142^ All were randomized controlled trials (RCTs). Total sample sizes ranged from 24 to 3,526. Most interventions included physical activity as a component. Inactive comparisons included health information and maintaining lifestyle habits. Conclusions are summarized in Table 4E.2 and individual study results in Table 4E.3.

Table 4E.2 Conclusions: Multimodal interventions versus inactive comparisons in adults with normal cognition

Intervention Components | Outcome | Conclusion | Strength of Evidence (justification)
Physical Activity and Diet k=2 | Dementia | No data available. | Insufficient (no data)
Physical Activity and Diet k=2 | MCI | No data available. | Insufficient (no data)
Physical Activity and Diet k=2 | Brief cognitive test performance | Limited data. | Insufficient (limited data)
Physical Activity and Diet k=2 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
Physical Activity and Diet k=2 | Executive/Attention/Processing speed | Unable to draw conclusion. | Insufficient (medium study limitations, indirect, imprecise, inconsistent)
Physical Activity and Diet k=2 | Memory | Limited data. | Insufficient (limited data)
Physical Activity and Cognitive Training k=1 | Dementia | No data available. | Insufficient (no data)
Physical Activity and Cognitive Training k=1 | MCI | No data available. | Insufficient (no data)
Physical Activity and Cognitive Training k=1 | Brief cognitive test performance | Limited data. | Insufficient (limited data)
Physical Activity and Cognitive Training k=1 | Multidomain neuropsychological performance | Limited data. | Insufficient (limited data)
Physical Activity and Cognitive Training k=1 | Executive/Attention/Processing speed | No data available. | Insufficient (no data)
Physical Activity and Cognitive Training k=1 | Executive/Attention /Processing speed | No data available. | Insufficient (no data)
Physical Activity, Diet, and Cognitive Training k=1 | Dementia | No data available. | Insufficient (no data)
Physical Activity, Diet, and Cognitive Training k=1 | MCI | No data available. | Insufficient (no data)
Physical Activity, Diet, and Cognitive Training k=1 | Brief cognitive test performance | No data available. | Insufficient (no data)
Physical Activity, Diet, and Cognitive Training k=1 | Multidomain neuropsychological performance | Intervention composed of diet, physical activity, and cognitive training improves multidomain neuropsychological test performance; unclear if improvement is clinically meaningful (n=1,260; 2 years). | Low (indirect, unknown consistency)
Physical Activity, Diet, and Cognitive Training k=1 | Executive/Attention/Processing speed | Intervention composed of diet, physical activity, and cognitive training improves executive/attention/processing speed; unclear if improvement is clinically meaningful (n=1,260; 2 years). | Low (indirect, unknown consistency)
Physical Activity, Diet, and Cognitive Training k=1 | Memory | Unable to draw conclusion (n=1,260; 2 years). | Insufficient (indirect, imprecise, inconsistent)
Physical Activity and Protein Supplementation k=1 | Dementia | No data available. | Insufficient (no data)
Physical Activity and Protein Supplementation k=1 | MCI | No data available. | Insufficient (no data)
Physical Activity and Protein Supplementation k=1 | Brief cognitive test performance | No data available. | Insufficient (no data)
Physical Activity and Protein Supplementation k=1 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
Physical Activity and Protein Supplementation k=1 | Executive/Attention/Processing speed | Limited data. | Insufficient (limited data)
Physical Activity and Protein Supplementation k=1 | Memory | Limited data. | Insufficient (limited data)
Goal Setting and Mentoring k=1 | Dementia | No data available. | Insufficient (no data)
Goal Setting and Mentoring k=1 | MCI | No data available. | Insufficient (no data)
Goal Setting and Mentoring k=1 | Brief cognitive test performance | Limited data. | Insufficient (limited data)
Goal Setting and Mentoring k=1 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
Goal Setting and Mentoring k=1 | Executive/Attention/Processing speed | Limited data. | Insufficient (limited data)
Goal Setting and Mentoring k=1 | Memory | Limited data. | Insufficient (limited data)
Individualized Lifestyle Advice and Medical Management k=1 | Dementia | No benefit to dementia risk from individualized intervention composed of lifestyle advice and medical management (n=526; 6 years). | Low (medium study limitations, direct, imprecise, unknown consistency)
Individualized Lifestyle Advice and Medical Management k=1 | MCI | No data available. | Insufficient (no data)
Individualized Lifestyle Advice and Medical Management k=1 | Brief cognitive test performance | No benefit in brief cognitive test performance from individualized intervention composed of lifestyle advice and medical management (n=526; 6 years). | Low (medium study limitations, indirect, unknown consistency)
Individualized Lifestyle Advice and Medical Management k=1 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
Individualized Lifestyle Advice and Medical Management k=1 | Executive/Attention/Processing speed | No data available. | Insufficient (no data)
Individualized Lifestyle Advice and Medical Management k=1 | Memory | No benefit to memory from individualized intervention composed of lifestyle advice and medical management (n=526; 6 years). | Low (medium study limitations, indirect, unknown consistency)

K=number of studies included; MCI=mild cognitive impairment; n=sample size

Table 4E.3 Results overview: Multimodal interventions versus inactive comparisons in adults with normal cognition

Author Year Comparison N= Followup | Diagnosis | Biomarkers [specific biomarker] | Brief Cognitive Test Performance/Multidomain Neuropsychological Test Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
Physical Activity and Diet Results Summary k=2; n=79 | NR | NR | BCT 1 of 1 favors I k=1 | 1 of 10 favors I k=2 | 0 of 11 (no difference) k=1 | 2 of 22 favor I | NR
Napoli, 2014^83^ Physical activity and diet vs. health information n=55 1 year | | | BCT I>C [3MS] | I>C [TMT A] | | 2 of 3 favor I | NR
Napoli, 2014^83^ Physical activity and diet vs. health information n=55 1 year | | | | NS [TMT B]
Martin, 2007^126^ Physical activity and diet vs. weight maintenance n=24 6 months | | | | NS [CPT-II, Beta (Response Style)] | NS [RAVLT, Trial I–V] | 0 of 19 (no difference) | NR
Martin, 2007^126^ Physical activity and diet vs. weight maintenance n=24 6 months | | | | NS [CPT-II, Omissions] | NS RAVLT, Trial B]
Martin, 2007^126^ Physical activity and diet vs. weight maintenance n=24 6 months | | | | NS [CPT-II, Detectability] | NS [RAVLT, Trial VI]
Martin, 2007^126^ Physical activity and diet vs. weight maintenance n=24 6 months | | | | NS [CPT-II, RT] | NS [RAVLT, Delayed Recall]
Martin, 2007^126^ Physical activity and diet vs. weight maintenance n=24 6 months | | | | NS [CPT-II, RT SE] | NS [RAVLT, Recognition]
Martin, 2007^126^ Physical activity and diet vs. weight maintenance n=24 6 months | | | | NS [CPT-II, Commissions] | NS [ACT, 9 sec]
Martin, 2007^126^ Physical activity and diet vs. weight maintenance n=24 6 months | | | | NS [CPT-II, Perseverations] | NS [ACT, 18 sec]
Martin, 2007^126^ Physical activity and diet vs. weight maintenance n=24 6 months | | | | NS [CPT-II, RT Block Changes] | NS [ACT, 36 sec]
Martin, 2007^126^ Physical activity and diet vs. weight maintenance n=24 6 months | | | | | NS [BVRT, Correct Deviation]
Martin, 2007^126^ Physical activity and diet vs. weight maintenance n=24 6 months | | | | | NS [BVRT, Error Deviation]
Martin, 2007^126^ Physical activity and diet vs. weight maintenance n=24 6 months | | | | | NS [BVRT, Correct Deviation]
Physical Activity and Cognitive Training Results Summary k=1; n=134 | NR | NR | BCT 0 fo1 (no difference) k=1 | 1 of 2 favors I k=1 | NR | 1 of 3 favors I | NR
Hars, 2014^135^ Physical activity and cognitive training vs. usual lifestyle n=134 6 months | | | BCT NS [MMSE] | NS [FAB] | | 1 of 2 favors I | NR
Hars, 2014^135^ Physical activity and cognitive training vs. usual lifestyle n=134 6 months | | | | I>C [Sensitivity to Inference Sub-test, FAB]
Physical Activity, Diet, and Cognitive Training Results Summary k=1; n=1,260 | NR | NR | MNP 1 of 1 favors I | 2 of 2 favors I k=1 | 1 of 2 favors I k=1 | 4 of 5 favors I
Ngandu, 2015^142^ Physical activity, diet, and cognitive training vs. health information n=1,260 2 years | | | MNP I>C [NTB, Total Score] | I>C NTB, Executive Functioning] | NS [NTB, Memory] | 4 of 5 favor I | Unclear [Musculoskeletal pain]
Ngandu, 2015^142^ Physical activity, diet, and cognitive training vs. health information n=1,260 2 years | | | | I>C NTB, Processing Speed] | I>C [NTB, Abbreviated Memory]
Physical Activity and Protein Supplementation Results Summary k=1; n=58 | NR | NR | NR | 1 of 11 favors I k=1 | 0 of 6 (no difference) k=1 | 1 of 17 favor I | NR
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=58 6 months | | | | NS [DS Forward] | NS [Word Learning Test, Immediate Recall-75 Words] | 1 of 17 favor I | NR
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=58 6 months | | | | NS [DS Backward] | NS [Word Learning Test, Delayed Recall-15 Words]
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=58 6 months | | | | NS [TMT A] | NS Word Learning Test, Decay]
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=58 6 months | | | | NS [SCWT 1] | NS [Word Learning Test, Recognition, 30 Words]
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=58 6 months | | | | NS [SCWT 2] | NS [Attention and Working Memory Composite]
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=58 6 months | | | | NS [SCWT Inference] | NS^z^ [Episodic Memory Composite]
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=58 6 months | | | | NS [RT Uncued]
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=58 6 months | | | | NS [RT Cued]
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=58 6 months | | | | NS [Word Fluency-Letter]
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=58 6 months | | | | I>C^z^ [Processing Speed Composite]
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=58 6 months | | | | NS^z^ [Executive Functioning Composite]
Goal Setting and Mentoring Results Summary k=1; n=75 | NR | NR | BCT 1 of 1 favors I k=1 | 1 of 1 favors I k=1 | 1 of 2 favors I 1 of 2 favors C k=1 | 3 of 4 favors I 1 of 4 favors C
Clare, 2015^133^ Goal setting and goal setting with mentoring vs. health information n=75 6 months | | | BCT I>C [MoCA] | I>C [TMT] | I>C [CVLT, Immediate Recall] | 3 of 4 favors I 1 of 4 favors C | NR
Clare, 2015^133^ Goal setting and goal setting with mentoring vs. health information n=75 6 months | | | | | C>I [CVLT, Delayed Recall]
Lifestyle Advice and Drug Treatment Summary k=1; n=3,526 | 1 of 4 favors I k=1 | NR | 0 of 1 (no difference) k=1 | NR | 0 of 1 (no difference) k=1 | 1 of 6 favors I
Moll van Charante, 2016^141^ Lifestyle advice and drug treatment vs. usual care n=3,526 6 years | NS [All-Cause Dementia] | NR | BCT NS [MMSE] | | NS [Visual Association Test A] | 1 of 6 favors I | NS [Severe Adverse Events]
Moll van Charante, 2016^141^ Lifestyle advice and drug treatment vs. usual care n=3,526 6 years | NS [AD]
Moll van Charante, 2016^141^ Lifestyle advice and drug treatment vs. usual care n=3,526 6 years | NS [Unspecified Dementia]
Moll van Charante, 2016^141^ Lifestyle advice and drug treatment vs. usual care n=3,526 6 years | I>C [Non-Alzheimer’s Dementia]

a mean global composite z score composed of xxx;

b composite z score of HVLT-R immediate and delayed word recall

3MS=Modified Mini-Mental State Examination; ACT=Auditory Consonant Trigram; AD=Alzheimer’s disease; BCT=Brief cognitive test performance; BVRT=Benton Visual Retention Test; C=inactive control; CPT=Continuous Performance Test; CVLT=California Verbal Learning Test; DS=Digit Span (Forward and/or Backward); FAB=Frontal Assessment Battery; I=Intervention; k=number of studies included; MMSE=Mini-Mental State Examination; MoCA=Montreal Cognitive Assessment; MNP=multidomain neuropsychological test performance; n=sample size; NR=not reported; NS=not significant; NTB=Neuropsychological Test Battery; RAVLT=Rey Auditory Verbal Learning Test; RT=reaction time; SE=standard error; SCWT=Stroop Color Word Test; TMT=Trail Making Test (Part A and/or B); vs.=versus.

Shading indicates summary rows and columns.

#### Physical Activity and Diet

Two trials (n=79) compared physical activity and diet with inactive controls.^83, 126^ Both enrolled overweight or obese adults. Napoli et al. randomized individuals to an intervention consisting of calorie-restriction diet and multicomponent exercise for 90 minutes, three times per week for 1 year.^83^ Martin et al. randomized overweight young to middle aged adults to a calorie restriction diet and structured exercise for 6 months.^126^

Neither trial reported diagnostic outcomes or multidomain neuropsychological test performance. Napoli et al. reported brief cognitive test performance for one measure (Modified Mini-Mental State Examination, 3MS) and found a statistically significant improvement with the physical activity and diet intervention compared with attention control.^83^ Martin et al. reports 11 measures of memory, none of which differed between physical activity with diet and attention control.^126^ Limited data prevented assessment of strength of evidence for brief cognitive test performance or memory.

Napoli et al. reported two measures of executive function/attention/processing speed,^83^ and Martin et al. reported eight.^126^ Napoli et al. showed statistically significant improvement in Trail Making Test A from baseline to 1 year in the multimodal intervention group compared with the health information group.^83^ The remaining nine measures from Napoli et al. and Martin et al. showed no statistically significant difference with multimodal intervention compared with attention control.^83, 126^ Evidence was insufficient to determine whether a multimodal intervention consisting of physical activity and diet improves executive function/attention/processing speed.

#### Physical Activity and Cognitive Training

Hars et al. (n=134) compared physical activity and cognitive training with an inactive control.^135^ Adults who were frail or had an increased risk of falling were randomized to a structured, music-based exercise or their usual lifestyle habits.^135^ The intervention involved weekly 60-minute structured music-based multitasking exercise classes for 6 months.

One measure of brief cognitive test performance (Mini-Mental State Examination, MMSE) showed no statistically significant improvements with the intervention compared with the control. Hars et al. also reported two measures of executive function.^135^ Overall, the Frontal Assessment Battery showed no statistically significant improvements with the intervention compared with the control; however, the Sensitivity to Inference subtest of the battery showed statistically significant improvements with the intervention. Limited data prevented assessment of strength of evidence for brief cognitive test performance or executive function. The trial reported on no other diagnoses, cognitive outcomes, biomarker measures, or harms.

#### Physical Activity, Diet, and Cognitive Training

Ngandu et al. (n=1,260) compared physical activity, diet, and cognitive training with an inactive control.^142^ Adults at risk for cardiovascular disease were randomized to a multimodal intervention (nutritional counseling, multicomponent exercise, cognitive training, and management of metabolic and vascular risk factors) or an attention control. The intervention involved one to three aerobic exercise sessions per week; two to five resistance training sessions per week; both group and individual cognitive training; and management of vascular risk factors with lifestyle changes for 2 years.

One measure of multidomain neuropsychological test performance was reported. The Neuropsychological Test Battery was significantly higher with multimodal intervention compared with control at 6 months. Low-strength evidence shows that a multimodal intervention consisting of physical activity, diet, and cognitive training improves multidomain neuropsychological performance when compared to attention control.

Three of four subtests (two executive function, two memory) of the Neuropsychological Test Battery showed statistical improvement with intervention compared with control at 6 months. Both executive function measures showed improvement; only one of the memory measures showed improvement. Low-strength evidence shows that a multimodal intervention consisting of physical activity, diet, and cognitive training improves executive function when compared to attention control.

Ngandu et al. reported no other diagnoses, cognitive outcomes, biomarker measures, or harms.^142^

#### Physical Activity and Protein Supplementation

Van de Rest et al. (n=58) compared physical activity and protein supplementation with usual care.^97^ Pre-frail and frail adults were randomized to resistance type exercise with protein supplementation or usual care (no exercise) and placebo for 6 months. The trial reported 11 measures of executive function. Only a composite score of processing speed showed a statistically significant difference between intervention and control groups at 6 months. The same trial also reported six measures of memory, none of which showed a statistically significant difference between groups at 6 months. This trial was likely underpowered. Evidence was insufficient to conclude whether physical activity and protein supplementation improves executive function or memory due to limited data.

Van de Rest et al. reported on no other diagnoses, cognitive outcomes, biomarker measures, or harms.^97^

#### Multimodal Goal Setting

Clare et al. (n=75) compared goal setting (with and without mentoring) with attention control.^133^ Functionally independent community-dwelling older adults participated in setting and discussing goals related to a variety of risk factors, then randomized to goal-setting alone or goal-setting with mentorship. Goal-setting involved an interview and identification of five goals; mentorship involved bi-monthly phone calls to discuss progress towards goals. Duration was 6 months.

Brief cognitive test performance (Montreal Cognitive Assessment), was better with the interventions compared to control. The trial also reported statistically significant improvements for the Trail-Making Test (executive function) and the Immediate Recall sub-test of the California Verbal Learning Test (CVLT) (memory) with intervention compared with control. However, the Delayed Recall subtest of the CVLT showed statistically significant improvements with attention control. Evidence was insufficient to conclude whether goal setting with mentoring improves cognitive outcomes due to limited data. The trial reported on no other diagnoses, cognitive outcomes, biomarker measures, or harms.

#### Lifestyle Advice and Drug Treatment

Moll van Charante et al. (n=3,526) reports on the Prevention of Dementia by Intensive Vascular care (PreDIVA) trial which compared a multimodal intervention that aimed to identify risks and provide individualized lifestyle advice and medical management with inactive control.^141^ Community-dwelling adults without dementia were randomized to a multimodal intervention (individualized lifestyle advice and, if indicated, medical management of chronic disease) or usual care (based on standards for cardiovascular risk management). The intervention consisted of visits for a general practice nurse every 4 months over 6 years. Nurses assessed cardiovascular risk factors (smoking habits, diet, physical activity, weight, and blood pressure), blood sugar, and cholesterol and provided individualized lifestyle advice based on these assessments. Subjects were prescribed drugs to manage identified cardiovascular risk factors, blood sugar, and cholesterol as needed. Antithrombotic drugs were also prescribed if needed.

At 6 years, there was no statistically significant difference between the intervention and control group in cases of all-cause dementia, Alzheimer’s disease, or unspecified types of dementia.^141^ Low strength evidence shows individualized multimodal intervention does not decrease dementia incidence.

There were statistically significant differences in cases of dementia in two subgroups: participants with untreated hypertension that were adherent to the intervention and participants without a history of cardiovascular disease who were adherent to the intervention. For both of these subgroups, there were fewer cases of dementia with the intervention.

One measure of brief cognitive test performance was reported. There was no statistically significant difference between intervention and control groups in MMSE scores at 6 years.^141^ In addition, one measure of memory was reported. There was no statistically significant difference between intervention and control groups in Visual Association Test A scores at 6 years. Low strength evidence shows individualized multimodal intervention does not benefit brief cognitive test performance or memory.

Moll van Charante et al. reported no difference in serious adverse effects between the intervention and control groups.^141^ The study reported no other diagnoses, cognitive outcomes, or biomarker measures.

### Comparative Effectiveness: Multimodal Interventions Versus Active Comparison

Multimodal interventions address several risk factors for CATD at once, potentially creating a synergistic protective effect. Studies compare multimodal interventions with single component interventions to test this hypothesis. Different approaches to multimodal interventions may also affect their potential effectiveness. This is tested in studies comparing different multimodal interventions.

Three studies with low to medium risk of bias compared multimodal interventions with active controls in adults with normal cognition.^62, 83, 126^ All were RCTs. Total sample sizes ranged from 24 to 134. All of the interventions included physical activity as a component. Active comparisons were a single component intervention (diet or physical activity alone). Individual study results are summarized in Table 4E.4. No conclusion table is provided since evidence to draw conclusions was insufficient due to limited data (single study with n<500) or no data.

Table 4E.4 Results overview: Multimodal interventions versus active comparisons in adults with normal cognition

Author Year Comparison N= Followup | Diagnosis | Biomarkers [specific biomarker] | Brief Cognitive Test Performance/Multidomain Neuropsychological Test Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
Physical Activity and Diet vs. Diet Results Summary k=2; n=102 | NR | NR | BCT 1 of 1 favors I k=1 | 0 of 18 (no difference) k=2 | 0 of 22 (no difference) k=1 | 1 of 41 favors I | NR
Napoli, 2014 ^83^ Physical activity and diet vs. diet n=54 1 year | | | BCT I>C [3MS] | NS [TMT A] | | 1 of 3 favors I | NR
Napoli, 2014 ^83^ Physical activity and diet vs. diet n=54 1 year | | | | NS [TMT B] | | | NR
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | NS [CPT-II, Beta (response style)] | NS [RAVLT, Trial I–V] | 0 of 19 (no difference)
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | NS [CPT-II, Omissions] | NS RAVLT, Trial B]
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | NS [CPT-II, Detectability] | NS [RAVLT, Trial VI]
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | NS [CPT-II, RT] | NS [RAVLT, Delayed Recall]
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | NS [CPT-II, RT SE] | NS [RAVLT, Recognition]
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | NS [CPT-II, Commissions] | NS [ACT, 9 sec]
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | NS [CPT-II, Perseverations] | NS [ACT, 18 sec]
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | NS [CPT-II, RT Block Changes] | NS [ACT, 36 sec]
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | | NS [BVRT, Correct Deviation]
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | | NS [BVRT, Error Deviation]
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | | NS [BVRT, Correct Deviation]
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | NS [CPT-II, Beta (response style)] | NS [RAVLT, Trial I–V] | 0 of 19 (no difference)
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | NS [CPT-II, Omissions] | NS RAVLT, Trial B]
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | NS [CPT-II, Detectability] | NS [RAVLT, Trial VI]
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | NS [CPT-II, Reaction time] | NS [RAVLT, Delayed Recall]
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | NS [CPT-II, RT Std. Error] | NS [RAVLT, Recognition]
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | NS [CPT-II, Commissions] | NS [ACT, 18 sec]
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | NS [CPT-II, Perseverations] | NS [ACT, 36 sec]
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | NS [CPT-II, RT Block Changes] | NS [BVRT, Correct Deviation]
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | | NS [BVRT, Error Deviation]
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | | NS [BVRT, Correct Deviation]
Martin, 2007^126^ Physical activity and diet vs. diet n=24 6 months | | | | | NS [ACT, 18 sec]
Physical Activity and Diet vs. Physical Activity Results Summary k=1; n=54 | NR | NR | BCT 0 of 1 (no difference) k=1 | 0 of 2 (no difference) k=1 | NR | 0 of 3 (no difference) | NR
Napoli, 2014^83^ Physical activity and diet vs. physical activity n=54 1 year | | | BCT NS [3MS] | NS [TMT A] | | 0 of 3 (no difference)
Napoli, 2014^83^ Physical activity and diet vs. physical activity n=54 1 year | | | | NS [TMT B]
Physical Activity and Cognitive Training vs. Cognitive Training Results Summary k=1; n=46 | NR | NR | NR | 0 of 7 (no difference) k=1 | 0 of 9 (no difference) k=1 | 0 of 9 (no difference) | NR
Eggenberger, 2015^62^ Physical activity and cognitive training vs. cognitive training n=46 6 months | | | | NS [TMT A] | NS [Story Recall] | 0 of 9 (no difference) | NR
Eggenberger, 2015^62^ Physical activity and cognitive training vs. cognitive training n=46 6 months | | | | NS [TMT B] | NS [PAL]
Eggenberger, 2015^62^ Physical activity and cognitive training vs. cognitive training n=46 6 months | | | | NS [Executive Control]
Eggenberger, 2015^62^ Physical activity and cognitive training vs. cognitive training n=46 6 months | | | | NS [DS Forward]
Eggenberger, 2015^62^ Physical activity and cognitive training vs. cognitive training n=46 6 months | | | | NS [Age Concentration Test A]
Eggenberger, 2015^62^ Physical activity and cognitive training vs. cognitive training n=46 6 months | | | | NS [Age Concentration Test B]
Eggenberger, 2015^62^ Physical activity and cognitive training vs. cognitive training n=46 6 months | | | | NS [DSST]

3MS=Modified Mini-Mental State Examination; ACT=Auditory Consonant Trigram; BCT=Brief cognitive test performance; BVRT=Benton Visual Retention Test; C=inactive control; CPT=Continuous Performance Test; DS=Digit Span (Forward and/or Backward); I=intervention; k=number of studies included; MNP=Multidomain neuropsychological test performance; n=sample size; NR=not reported; NS=not significant; NTB=Neuropsychological Test Battery; PAL=Paired Associations Learning Test; RAVLT=Rey Auditory Verbal Learning Test; RT=reaction time; SE=standard error; TMT=Trail Making Test (Part A and/or B); vs.=versus.

Shading indicates summary rows and columns.

#### Physical Activity and Diet Versus Single-Component

Two trials (n=90) compared physical activity and diet changes with a single component (diet or physical activity).^83, 126^ Napoli et al. reported brief cognitive test performance (3MS) and several measured of executive function/attention/processing speed outcomes using several instruments, and found no statistically significant improvement with physical activity and diet compared to either single component intervention.^83^

Martin et al. compared physical activity and diet intervention with two diet interventions alone (calorie restriction alone and liquid calorie diet alone).^126^ Across both comparisons, the trial reports 22 measures of memory and several measured of executive function/attention/processing speed outcomes using several instruments, none of which showed statistical differences between the physical activity and diet intervention compared with either diet alone. Evidence was inadequate to assess the strength of evidence for brief cognitive test performance or memory.

The trials reported no additional outcomes.

#### Multimodal Versus Multimodal

Eggenberger et al. (n=46) compared two interventions that each had a physical activity and cognitive training component.^62^ Older adults were randomized to either virtual reality game dancing with cognitive training or to treadmill walking with verbal memory exercise. The trial reported seven measures of executive function that showed no statistically significant differences between the intervention groups. The trial also reported two measures of memory that showed no statistically significant differences between the intervention groups. Evidence was insufficient to determine whether different multimodal interventions consisting of physical activity and cognitive training improves executive function/attention/processing speed due to limited data. The trial reported no additional outcomes.

## Adults With MCI

Only two unique studies compared multimodal interventions to inactive controls in older adults with MCI^66, 136^ and two unique studies comparing multimodal interventions with active interventions in older adults with MCI.^66, 72^ All were RCTs assessed as high risk of bias.

## Interpreting the Findings

The available evidence is largely insufficient to draw conclusions about the effectiveness of an array of multimodal interventions for cognitive performance or progression to MCI or CATD, largely because the evidence base is weak with small trials of heterogeneous interventions. One important trial does provide sufficient evidence regarding multimodal interventions – the FINGER trial provided low-strength evidence that a combination of physical activity, diet changes, and cognitive training improved multidomain neuropsychological performance and executive function in adults at risk for MCI or CATD, although whether the improvement is clinically meaningful is unclear.^142^

The results of PreDiva study showed no difference between the multimodal and usual care for most outcomes; however, the intervention had no specific cognitive training, physical activity, or diet component.^141^ Subjects were counseled to make lifestyle changes, but no specific regimen was implemented. In addition, a large number of participants discontinued the intervention over the 6-year period (final outcomes were obtained through medical records). Results of the ongoing MAPT trial, another large well-designed trial, may provide additional clarity regarding the efficacy and effectiveness of multimodal interventions.^14^

The risk of bias and small sample sizes of identified studies were substantial barriers to our analysis. Of the 20 eligible studies, only eight were of low to medium risk of bias. None of the trials examining multimodal interventions for individuals with MCI were analyzed due to high risk of bias. For adults with normal cognition, nearly all trials had sample sizes less than 100. Multimodal studies make sense to test two concepts: 1) additive effects of strong interventions and 2) overall effects of combinations. The first strategy uses a control of one of the components. The second compares the combination to a control group. The second strategy may facilitate the search for interventions. If a combination does not work, then either component alone likely will not. If it does work, one can compare the marginal benefit of adding the second component.

* Note that the literature currently does not use the term CATD; we specified whenever the diagnosis of dementia was defined.