# 4D Results: Diet Interventions

## Key Messages

- Evidence is insufficient to conclude whether protein supplementation or energy-deficit diets have an effect on cognitive performance or incidence of mild cognitive impairment (MCI) or clinical Alzheimer’s-type dementia (CATD)^*^.

## Eligible Studies

We identified nine eligible publications reporting six unique studies evaluating the effect of diet interventions to prevent age-related cognitive decline, MCI, or CATD.^69, 83, 125–131^ Six studies were high risk of bias (including studies of the Mediterranean diet) and not used in our analysis. All eligible studies enrolled participants with normal cognition. Appendix I provides evidence tables and summary risk of bias assessments.

## Logic of Diet Interventions

Several mechanisms are suggested to link diet to cognitive function and then to age-related cognitive decline, MCI, and CATD. Among these include the link between obesity and CATD with a dietary intervention leading to weight loss and decreased risk.^83, 125^ Another proposed mechanism involves the effect of antioxidants (diets rich in these foods) on oxidative stress and vascular impairment, decreasing risk.^129^

## Adults With Normal Cognition

No conclusion table is provided since evidence to draw conclusions was insufficient due to limited data (single study with n<500) or no data.

### Protein Supplement Versus Placebo

Van der Zwaluw et al. compared a protein supplement drink versus a placebo.^130^ Sixty-five older adults were randomized to receive either 15mg of protein twice daily or a placebo drink for 24 weeks. No diagnostic outcomes were reported. Despite administering numerous cognitive tests, no statistically significant differences were found in change in executive function/attention/processing speed or memory function. Individual study results are summarized in Table 4D.1. Evidence was insufficient (limited data) to conclude whether protein supplementation has an effect on cognitive outcomes when compared to placebo.

Table 4D.1 Results overview: Diet interventions in adults with normal cognition

Author Year Comparison N= Followup | Diagnosis | Biomarkers [specific biomarker] | Brief Cognitive Test Performance/Multidomain Neuropsychological Test Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
Protein Supplement vs. Placebo Results Summary k=1; n=65 | NR | NR | NR | 0 of 13 (no difference) k=1 | 0 of 3 (no difference) k=1 | 0 of 16 (no difference) | NR
van der Zwaluw, 2014^130^ Protein drink (15 mg of protein) twice daily vs. placebo n=65 24 weeks | | | | NS [DS Forward] | NS [WLT, Immediate] | 0 of 16 (no difference) | NR
van der Zwaluw, 2014^130^ Protein drink (15 mg of protein) twice daily vs. placebo n=65 24 weeks | | | | NS [DS Backward] | NS [WLT, Delayed]
van der Zwaluw, 2014^130^ Protein drink (15 mg of protein) twice daily vs. placebo n=65 24 weeks | | | | NS [TMT A] | NS [WLT, Recognition]
van der Zwaluw, 2014^130^ Protein drink (15 mg of protein) twice daily vs. placebo n=65 24 weeks | | | | NS [SCWT 1]
van der Zwaluw, 2014^130^ Protein drink (15 mg of protein) twice daily vs. placebo n=65 24 weeks | | | | NS [SCWT 2]
van der Zwaluw, 2014^130^ Protein drink (15 mg of protein) twice daily vs. placebo n=65 24 weeks | | | | NS [SCWT 3]
van der Zwaluw, 2014^130^ Protein drink (15 mg of protein) twice daily vs. placebo n=65 24 weeks | | | | NS [RT Test]
van der Zwaluw, 2014^130^ Protein drink (15 mg of protein) twice daily vs. placebo n=65 24 weeks | | | | NS [TMT B/A]
van der Zwaluw, 2014^130^ Protein drink (15 mg of protein) twice daily vs. placebo n=65 24 weeks | | | | NS [Word Fluency, Animals]
van der Zwaluw, 2014^130^ Protein drink (15 mg of protein) twice daily vs. placebo n=65 24 weeks | | | | NS [Word Fluency, Letter P]
van der Zwaluw, 2014^130^ Protein drink (15 mg of protein) twice daily vs. placebo n=65 24 weeks | | | | NS [Composite]
van der Zwaluw, 2014^130^ Protein drink (15 mg of protein) twice daily vs. placebo n=65 24 weeks | | | | NS [Composite]
van der Zwaluw, 2014^130^ Protein drink (15 mg of protein) twice daily vs. placebo n=65 24 weeks | | | | NS [Composite]
Energy Restriction Results Summary k=1; n=53 | NR | NR | 1 of 1 favors I | 0 of 2 (no difference) | NR | 1 of 3 favors I | NR
Napoli, 2014^83^ Energy deficit of 500–750 kcal/d from daily requirements vs. control n=53 1 year | | | BCT I>C [3MS] | | | 1 of 3 favors I | NR
Napoli, 2014^83^ Energy deficit of 500–750 kcal/d from daily requirements vs. control n=53 1 year | | | | NS [TMT A]
Napoli, 2014^83^ Energy deficit of 500–750 kcal/d from daily requirements vs. control n=53 1 year | | | | NS [TMT B]

3MS=Modified Mini-Mental State Examination; BCT=brief cognitive test performance; C=control; DS=Digit Span (Forward and/or Backward); k=number of studies included; kcal/d=calories per day; I=intervention; n=sample size; MNP=multidomain neuropsychological test performance; NR=not reported; NS=no statistically significant difference; RT=reaction time; SCWT=Stroop Color/Word Test; TMT=Trail Making Test (Part A and/or B); vs.=versus; WLT=Word Learning Test.

Shading indicates summary rows and columns.

### Energy-Deficit Diet Versus Inactive Control

Napoli et al. reported a single randomized controlled trial (RCT) with medium risk of bias enrolling a total of 107 adults that compared a diet intervention with inactive controls in adults with normal cognition.^83^ The intervention consisted of an energy-deficit diet (500–750 kcal per day) while setting weekly behavioral goals and attending weekly weigh-in sessions. A weight-loss goal of approximately 10 percent was to be achieved at 6 months, followed by weight maintenance for the remaining 6 months. (Weight loss of −9.7 ± 5.4 kg was reported for the diet group while the control group weight was reported as stable.) The control comparisons consisted of diet education with a prohibition on participating in any weight-loss or exercise program. Individual study results are summarized in Table 4D.1. Evidence was insufficient (limited data) to conclude whether energy-deficit diets have an effect on cognitive outcomes when compared to attention control.

## Adults With MCI

No studies address adults with MCI.

## Interpreting the Findings

Diet interventions are challenging to study as demonstrated by the proportion of eligible studies that were high risk of bias.

* Note that the literature currently does not use the term CATD; we specified whenever the diagnosis of dementia was defined.