# 4C Results: Nutraceutical Interventions

## Key Messages

- Low-strength evidence suggests omega-3 fatty acids and ginkgo biloba did not improve clinical Alzheimer’s-type dementia (CATD)^*^ incidence or cognitive performance in adults with normal cognition.
- Evidence is insufficient to conclude whether resveratrol or plant sterol/stanol esters reduced CATD incidence or improved cognitive performance in adults with normal cognition.
- Few studies examined the effects of nutraceuticals on adults with mild cognitive impairment (MCI).

## Eligible Studies

We identified 25 eligible publications reporting 23 unique studies of nutraceutical interventions to prevent age-related cognitive decline, MCI, or CATD.^59, 101–124^ Eight were assessed as high risk of bias and not used in our analysis, leaving 15 studies to use in our analysis. We analyzed the efficacy and comparative effectiveness of nutraceutical interventions separately for adults with normal cognition and those with MCI. Appendix H provides evidence tables, summary risk of bias assessments, and assessments of strength of evidence for key comparisons and outcomes.

## Logic of Nutraceutical Interventions

The logic underlying nutraceuticals varies with the nutraceutical. Targeted pathways include reducing oxidative stress and chronic inflammation, improving vascular function, and supplementing macronutrients found in brain tissue and used in brain function.

## Adults With Normal Cognition

Conclusions are summarized in Table 4C.1 and individual study results in Table 4C.2.

Table 4C.1 Conclusions: Nutraceuticals in adults with normal cognition

Comparison | Outcome | Conclusion | Strength of Evidence (justification)
Omega-3 fatty acids vs. inactive control k=7 | Dementia | No statistically significant difference in dementia diagnosis with omega-3 fatty acids versus placebo in long term (n=12,536; 6 years; adults with diabetes or glucose intolerance). | Low (high study limitations of composite outcome with component of unequal importance, one of which is not clinical diagnosis and may be achieved due to chance, unknown consistency)
Omega-3 fatty acids vs. inactive control k=7 | MCI | No data available. | Insufficient (no data)
Omega-3 fatty acids vs. inactive control k=7 | Brief cognitive test performance | No benefit in brief cognitive test performance with omega-3 fatty acids versus placebo in long term (n=16,431; up to 6 years). | Low (medium study limitations, indirect, imprecise)
Omega-3 fatty acids vs. inactive control k=7 | Multidomain neuropsychological performance | No benefit in multidomain neuropsychological performance with omega-3 fatty acids versus placebo in long term (n=744; 2 years). | Low (medium study limitations, indirect, imprecise, unknown consistency)
Omega-3 fatty acids vs. inactive control k=7 | Executive/Attention/Processing speed | No benefit in executive/attention/processing speed with omega-3 fatty acids versus placebo in long term (n=5,079; up to 6 years). | Low (medium study limitations, indirect, imprecise)
Omega-3 fatty acids vs. inactive control k=7 | Memory | No benefit in memory with omega-3 fatty acids versus placebo in long term (n=3,428; up to 4 years). | Low (medium study limitations, indirect, imprecise)
Omega-3 fatty acids vs. B vitamins (folate, B_6_, B_12_) k=1 | Dementia | No data available. | Insufficient (no data)
Omega-3 fatty acids vs. B vitamins (folate, B_6_, B_12_) k=1 | MCI | No data available. | Insufficient (no data)
Omega-3 fatty acids vs. B vitamins (folate, B_6_, B_12_) k=1 | Brief cognitive test performance | No benefit in brief cognitive test performance with omega-3 fatty acids versus vitamin B in long term (n=885; 4 years). | Low (medium study limitations, indirect, imprecise, unknown consistency)
Omega-3 fatty acids vs. B vitamins (folate, B_6_, B_12_) k=1 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
Omega-3 fatty acids vs. B vitamins (folate, B_6_, B_12_) k=1 | Executive/Attention/Processing speed | No data available. | Insufficient (no data)
Omega-3 fatty acids vs. B vitamins (folate, B_6_, B_12_) k=1 | Memory | No benefit in memory with omega-3 fatty acids versus vitamin B in long term (n=885; 4 years). | Low (medium study limitations, indirect, imprecise, unknown consistency)
Omega-3 + B vitamins (folate, B_6_, B_12_) vs. B vitamins (folate, B_6_, B_12_) k=1 | Dementia | No data available. | Insufficient (no data)
Omega-3 + B vitamins (folate, B_6_, B_12_) vs. B vitamins (folate, B_6_, B_12_) k=1 | MCI | No data available. | Insufficient (no data)
Omega-3 + B vitamins (folate, B_6_, B_12_) vs. B vitamins (folate, B_6_, B_12_) k=1 | Brief cognitive test performance | No benefit in brief cognitive test performance with B vitamins and omega-3 versus B vitamins alone in long term (n=884; 4 years). | Low (low study limitations, indirect, imprecise, consistency unknown)
Omega-3 + B vitamins (folate, B_6_, B_12_) vs. B vitamins (folate, B_6_, B_12_) k=1 | Multidomain neuropsychological performances | No data available. | Insufficient (no data)
Omega-3 + B vitamins (folate, B_6_, B_12_) vs. B vitamins (folate, B_6_, B_12_) k=1 | Executive/Attention/Processing speed | No data available. | Insufficient (no data)
Omega-3 + B vitamins (folate, B_6_, B_12_) vs. B vitamins (folate, B_6_, B_12_) k=1 | Memory | No benefit in memory with B vitamins with omega-3 versus B vitamins alone in long term (n=884; 4 years). | Low (low study limitations, indirect, imprecise, consistent)
Ginkgo biloba vs. inactive control k=3 | Dementia | No statistically significant difference in dementia diagnosis with ginkgo biloba versus placebo in long term (n=5,407; 6 years; adults over 70). | Low (medium study limitations, direct, imprecise, consistent)
Ginkgo biloba vs. inactive control k=3 | MCI | Limited data. | Insufficient (limited data)
Ginkgo biloba vs. inactive control k=3 | Brief cognitive test performance | No data available. | Insufficient (no data)
Ginkgo biloba vs. inactive control k=3 | Multidomain neuropsychological performance | No benefit in multidomain neuropsychological performance with ginkgo biloba versus placebo in long term (n=3,069; 6 years, adults over 70). | Low (medium study limitation, indirect, imprecise, unknown consistency)
Ginkgo biloba vs. inactive control k=3 | Executive/Attention/Processing speed | No benefit in executive/attention/processing speed with ginkgo biloba versus placebo in long term (n=5,079; 6 years, adults over 70). | Low (medium study limitation, indirect, imprecise)
Ginkgo biloba vs. inactive control k=3 | Memory | No benefit in memory with ginkgo biloba versus placebo in long term (n=3,187; up to 6 years, adults over 70). | Low (medium study limitation, indirect, imprecise)

k=number of studies included; MCI=mild cognitive impairment; n=sample size; vs.=versus

Table 4C.2 Results Overview: Nutraceuticals in adults with normal cognition

Author Year Comparison N=Follow-up | Diagnosis | Biomarkers [specific biomarker] | Brief Cognitive Test Performance/Multidomain Neuropsychological Test Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
Omega-3 Results Summary k=7; n=21,027 | 0 of 1 (no difference) k=1 | 1 of 2 favor I k=2 | BCT 0 of 9 (no difference) k=4 MNP 0 of 1 (no difference) k=1 | 2 of 31 favor I k=5 | 3 of 25 favor I k=1 | 6 of 68 favor I | 0 of 4 (no difference) k=2
Cukierman-Yaffe, 2014^120^ Omega-3 (EPA 465 mg + DHA 375 mg daily) n=15,077 Median 6.2 years | NS [Incident probable cognitive impairment = reported dementia or an MMSE score of < 24] (n=12,536) | | BCT NS [MMSE] (n=11,685) | NS [DSST] (n=3,392) | | 0 of 2 favor I | NR
Witte, 2014^117^ Omega-3 (fish oil LC-n3-FA) 2.2 grams daily vs. placebo n=65 6 months | | I>C [MRI - Gray Matter Volume] | | I>C [Executive Composite: Phonemic & Semantic Fluency, TMT A & B, SCWT Parts 1–3] | Ns [Memory Composite: AVLT Learning, Delayed Recall, Recognition, DS Backward] | 2 of 6 favor I | NR
Witte, 2014^117^ Omega-3 (fish oil LC-n3-FA) 2.2 grams daily vs. placebo n=65 6 months | | NS [MRI - White Matter Integrity] | | NS [Sensorimotor Speed Composite: TMT A, SCWT A & B]
Witte, 2014^117^ Omega-3 (fish oil LC-n3-FA) 2.2 grams daily vs. placebo n=65 6 months | | | | NS [DS Forward]
Geleijnse, Geleijnse 2012^107^ Omega-3 (EPA-DHA 400mg/d) vs. placebo n=2,522 40 months | | | BCT NS [MMSE] | | | 0 of 3 (no difference)
Geleijnse, Geleijnse 2012^107^ Omega-3 (EPA-DHA 400mg/d) vs. placebo n=2,522 40 months | | | BCT NS [Risk of Moderate/Severe Cog Decline, MMSE]^a^
Geleijnse, Geleijnse 2012^107^ Omega-3 (EPA-DHA 400mg/d) vs. placebo n=2,522 40 months | | | BCT NS [Risk of Severe Cog Decline, MMSE]^b^
Geleijnse, 2012^107^ Omega-3 (ALA 200mg/d) vs. placebo n=2,522 40 months | | | BCT NS [MMSE] | | | 0 of 3 (no difference) | NR
Geleijnse, 2012^107^ Omega-3 (ALA 200mg/d) vs. placebo n=2,522 40 months | | | BCT NS [Risk of Moderate/Severe Cog Decline, MMSE]^a^
Geleijnse, 2012^107^ Omega-3 (ALA 200mg/d) vs. placebo n=2,522 40 months | | | BCT NS [Risk of Severe Cog Decline, MMSE]^b^
Andreeva, 2011 ^101^ Omega-3 (EPA-DHA 600 mg/d in a 2:1 ratio) vs. placebo n=1,741 4 years | | | BCT NS [F-TICS Overall Score] | | NS [F-TICS Attention & Semantic Memory Subscore] | 0 of 3 (no difference) | NR
Andreeva, 2011 ^101^ Omega-3 (EPA-DHA 600 mg/d in a 2:1 ratio) vs. placebo n=1,741 4 years | | | | | NS [F-TICS Recall/Repetition Subscore]
Dangour, 2010 ^103^ Omega-3 (EPA 200 mg/d + DHA 500 mg/d) vs. placebo n=744 2 years | | | MNP NS [Global Composite]^c^ | NS [Executive Composite: CVLT Delayed Recall, Location Memory Delayed Recall, Story Recall Delayed] | NS [CVLT – Words Correct] | 0 of 17 (no difference) | NS [hospitalization for stroke or MI]
Dangour, 2010 ^103^ Omega-3 (EPA 200 mg/d + DHA 500 mg/d) vs. placebo n=744 2 years | | | | NS [Processing Speed Composite: Letter Cancellation, Simple RT, Choice RT, DSST] | NS [CVLT - Delayed Recall]
Dangour, 2010 ^103^ Omega-3 (EPA 200 mg/d + DHA 500 mg/d) vs. placebo n=744 2 years | | | | NS [Letter Search/Cancellation] | NS [Memory Composite: CVLT Sum of Words, CVLT Delayed Recall, Location Memory & Delayed, Story Recall & Delayed]
Dangour, 2010 ^103^ Omega-3 (EPA 200 mg/d + DHA 500 mg/d) vs. placebo n=744 2 years | | | | NS [SDMT] | NS [Global Delay Composite: CVLT Delayed Recall, Location Memory Delayed Recall, Story Recall delayed]
Dangour, 2010 ^103^ Omega-3 (EPA 200 mg/d + DHA 500 mg/d) vs. placebo n=744 2 years | | | | NS [RT, Simple] | NS [Story Recall - Immediate]
Dangour, 2010 ^103^ Omega-3 (EPA 200 mg/d + DHA 500 mg/d) vs. placebo n=744 2 years | | | | NS [RT, Choice] | NS [Story Recall - Delayed]
Dangour, 2010 ^103^ Omega-3 (EPA 200 mg/d + DHA 500 mg/d) vs. placebo n=744 2 years | | | | NS [DS Forward] | NS [Spatial Memory - Immediate]
Dangour, 2010 ^103^ Omega-3 (EPA 200 mg/d + DHA 500 mg/d) vs. placebo n=744 2 years | | | | NS [DS Backward] | NS [Spatial Memory - Delayed]
Yurko-Mauro, 2010^119^ Omega-3 (DHA 900 mg/d) n=483 6 months | | | BCT NS [MMSE] | I>C [CANTAB Stockings of Cambridge] | I>C [CANTAB PAL Battery] | 4 of 8 favor I | NS [Infection]
Yurko-Mauro, 2010^119^ Omega-3 (DHA 900 mg/d) n=483 6 months | | | | | NS [CANTAB VRM – Free Recall] | | NS [Musculoskeletal]
Yurko-Mauro, 2010^119^ Omega-3 (DHA 900 mg/d) n=483 6 months | | | | | I>C [CANTAB VRM - Immediate Recall] | | NS [Gastrointestinal]
Yurko-Mauro, 2010^119^ Omega-3 (DHA 900 mg/d) n=483 6 months | | | | | I>C [CANTAB VRM - Delayed Recall] | | NS [Nervous System]
Yurko-Mauro, 2010^119^ Omega-3 (DHA 900 mg/d) n=483 6 months | | | | | NS [CANTAB SWM]
Yurko-Mauro, 2010^119^ Omega-3 (DHA 900 mg/d) n=483 6 months | | | | | NS [CANTAB PRM - Delayed]
Van de Rest, 2008^115^ Omega-3 (EPA-DHA 400 mg/d) vs. placebo n=196 6 months | | | | NS [Executive Composite: TMT A & B, SCWT Part 3: (part 1 + part 2/2), Word Fluency Animals & Letter] | NS [Memory Composite: Word Learning Immediate, Delayed, & Recognition, DS Backward] | 0 of 13 (no difference)
Van de Rest, 2008^115^ Omega-3 (EPA-DHA 400 mg/d) vs. placebo n=196 6 months | | | | NS [Attention Composite] | NS [Word Learning - Immediate Recall]
Van de Rest, 2008^115^ Omega-3 (EPA-DHA 400 mg/d) vs. placebo n=196 6 months | | | | NS [DS Forward] | NS [Word Learning - Delayed Recall]
Van de Rest, 2008^115^ Omega-3 (EPA-DHA 400 mg/d) vs. placebo n=196 6 months | | | | NS [DS Backward] | NS [Word Learning - Recognition]
Van de Rest, 2008^115^ Omega-3 (EPA-DHA 400 mg/d) vs. placebo n=196 6 months | | | | NS [TMT A]
Van de Rest, 2008^115^ Omega-3 (EPA-DHA 400 mg/d) vs. placebo n=196 6 months | | | | NS [TMT B]
Van de Rest, 2008^115^ Omega-3 (EPA-DHA 400 mg/d) vs. placebo n=196 6 months | | | | NS [SCWT Part 1]
Van de Rest, 2008^115^ Omega-3 (EPA-DHA 400 mg/d) vs. placebo n=196 6 months | | | | NS [SCWT Part 2]
Van de Rest, 2008^115^ Omega-3 (EPA-DHA 400 mg/d) vs. placebo n=196 6 months | | | | NS [SCWT Part 3: (part 1 + part 2/2)]
Van de Rest, 2008^115^ Omega-3 (EPA-DHA 1800 mg/d) vs. placebo n=199 6 months | | | | NS [Executive Composite (Same As Immediately Above)] | NS [Memory Composite (Same As Immediately Above)] | 0 of 13 (no difference)
Van de Rest, 2008^115^ Omega-3 (EPA-DHA 1800 mg/d) vs. placebo n=199 6 months | | | | NS [Attention Composite] | NS [Word Learning, Immediate Recall]
Van de Rest, 2008^115^ Omega-3 (EPA-DHA 1800 mg/d) vs. placebo n=199 6 months | | | | NS [DS Forward] | NS [Word Learning, Delayed Recall]
Van de Rest, 2008^115^ Omega-3 (EPA-DHA 1800 mg/d) vs. placebo n=199 6 months | | | | NS [DS Backward] | NS [Word Learning, Recognition]
Van de Rest, 2008^115^ Omega-3 (EPA-DHA 1800 mg/d) vs. placebo n=199 6 months | | | | NS [TMT A]
Van de Rest, 2008^115^ Omega-3 (EPA-DHA 1800 mg/d) vs. placebo n=199 6 months | | | | NS [TMT B]
Van de Rest, 2008^115^ Omega-3 (EPA-DHA 1800 mg/d) vs. placebo n=199 6 months | | | | NS [SCWT Part 1]
Van de Rest, 2008^115^ Omega-3 (EPA-DHA 1800 mg/d) vs. placebo n=199 6 months | | | | NS [SCWT Part 2]
Van de Rest, 2008^115^ Omega-3 (EPA-DHA 1800 mg/d) vs. placebo n=199 6 months | | | | NS [SCWT Part 3: (part 1 + part 2/2)]
B vitamins (folate/B_6_/B_12_) vs. omega-3 Results Summary k=1; n=885 | NR | NR | 0 of 1 (no difference) k=1 | NR | 0 of 2 (no difference) k=1 | 0 of 3 (no difference) | NR
Andreeva, 2011^101^ B vitamins (folate, B_6_, B_12_) vs. Omega-3 n=885 4 years | | | BCT NS [TICS] | | NS [TICS Memory] | 0 of 3 (no difference) | NR
Andreeva, 2011^101^ B vitamins (folate, B_6_, B_12_) vs. Omega-3 n=885 4 years | | | | | NS [TICS Recall]
B vitamins (folate/B_6_/B_12_) + omega-3 vs. B vitamins Results Summary k=1; n=884 | NR | NR | 0 of 1 (no difference) k=1 | NR | 0 of 2 (no difference) k=1 | 0 of 3 (no difference) | NR
Andreeva, 2011^101^ B vitamins (folate, B_6_, B_12_) + omega-3 vs. B vitamins (folate, B_6_, B_12_) n=884 4 years | | | BCT NS [TICS] | | NS [TICS Memory] | 0 of 3 (no difference) | NR
Andreeva, 2011^101^ B vitamins (folate, B_6_, B_12_) + omega-3 vs. B vitamins (folate, B_6_, B_12_) n=884 4 years | | | | | NS [TICS Recall]
Ginkgo biloba Results Summary k=3; n=6,041 | 0 of 11 (no difference) k=3 | NR | MNP 0 of 1 (no difference) k=1 | 0 of 5 (no difference) k=1 | 0 of 4 (no difference) k=2 | 0 of 10 (no difference) | All serious AEs NS except C>1 [Stroke/TIA]
Vellas, 2012^116^ Ginkgo biloba extract (EGb761) 120 mg twice daily vs. placebo n=2,820 5 years | NS [Incidence of Probable CATD, Each Year For 5 Years] | | | | | No intermediate outcomes reported | NS [stroke, haemorrhagic events, cardiac disorders]
Snitz, 2009^113^ DeKosky 2008^104^ Ginkgo biloba extract 120 mg twice daily n=3,069 (normal cog & MCI, cognitive test results) n=2,587 (incident AD/dementia) Median 6.1 years | NS [All Dementia] | | MNP NS [Composite: 3MS & ADAS-Cog] | NS [Executive Composite: TMT B & SCWT] | NS [Memory Composite: CVLT & Recall Conditions - Modified RCFT] | 0 of 9 (no difference) | NS [mortality, CHD, stroke, major bleeding]
Snitz, 2009^113^ DeKosky 2008^104^ Ginkgo biloba extract 120 mg twice daily n=3,069 (normal cog & MCI, cognitive test results) n=2,587 (incident AD/dementia) Median 6.1 years | NS [CATD Without Vascular Dementia] | | | NS [Attention & Psychomotor Speed Composite: WAIS-R DS & TMT A] | NS [CVLT]
Snitz, 2009^113^ DeKosky 2008^104^ Ginkgo biloba extract 120 mg twice daily n=3,069 (normal cog & MCI, cognitive test results) n=2,587 (incident AD/dementia) Median 6.1 years | NS [CATD With Vascular Dementia] | | | NS [TMT B] | NS [Recall Conditions - Modified RCFT]
Snitz, 2009^113^ DeKosky 2008^104^ Ginkgo biloba extract 120 mg twice daily n=3,069 (normal cog & MCI, cognitive test results) n=2,587 (incident AD/dementia) Median 6.1 years | NS [total CATD] | | | NS [TMT A]
Snitz, 2009^113^ DeKosky 2008^104^ Ginkgo biloba extract 120 mg twice daily n=3,069 (normal cog & MCI, cognitive test results) n=2,587 (incident AD/dementia) Median 6.1 years | | | | NS [WAIS-R DS]
Dodge, 2008^105^ Ginkgo biloba extract 80 mg three times daily n=118 3 years 6 months | NS [MCI Diagnosis Estimate: Progress from CDR 0 to CDR 0.5] | | | | NS [CERAD Word List Delayed Recall] | 0 of 1 (no difference) | C>I [Stroke/TIA] [AEs in treatment group]
Dodge, 2008^105^ Ginkgo biloba extract 80 mg three times daily n=118 3 years 6 months | | | | | | | NS [Cardiac, renal, falls, other]
Resveratrol Results Summary k=1; n=46 | NR | 3 of 5 favor I k=1 | NR | NR | 2 of 6 favor I k=1 | 5 of 11 favor I | NR
Witte, 2014^118^ Resveratrol 200 mg daily n=46 6 months (Resveratrol is a member of a group of plant compounds called polyphenols with possible antioxidant properties) | | NS [Total Gray Matter Volume] | | | I>C [Memory Composite: AVLT Retention, Delayed Recall, Recognition, Learning Ability, 5th Learning Trial] | 5 of 11 favor I
Witte, 2014^118^ Resveratrol 200 mg daily n=46 6 months (Resveratrol is a member of a group of plant compounds called polyphenols with possible antioxidant properties) | | NS [HC Microstructure] | | | I>C [AVLT Retention]
Witte, 2014^118^ Resveratrol 200 mg daily n=46 6 months (Resveratrol is a member of a group of plant compounds called polyphenols with possible antioxidant properties) | | I>C [Functional Capacity, HC Frontal] | | | NS [AVLT Delayed Recall]
Witte, 2014^118^ Resveratrol 200 mg daily n=46 6 months (Resveratrol is a member of a group of plant compounds called polyphenols with possible antioxidant properties) | | I>C [Functional Capacity, HC Parietal] | | | NS [AVLT Recognition]
Witte, 2014^118^ Resveratrol 200 mg daily n=46 6 months (Resveratrol is a member of a group of plant compounds called polyphenols with possible antioxidant properties) | | I>C [Functional Capacity, HC Occipital] | | | NS [AVLT Learning Ability]
Witte, 2014^118^ Resveratrol 200 mg daily n=46 6 months (Resveratrol is a member of a group of plant compounds called polyphenols with possible antioxidant properties) | | | | | NS [AVLT Fifth Learning Trial]
Plant Sterols/Stanols Results Summary | NR | NR | NR | 0 of 3 (no difference) k=1 | 0 of 1 (no difference) k=1 | 0 of 4 (no difference) | NR
Schiepers, 2009^111^ Margarines enriched with plant sterol esters (2.5 g/d) or plant stanol esters (2.5 g/d) n=57 1.6 years (85 weeks) | | | | NS [Simple Information Processing Speed Composite: SCWT 1 & 2, Concept Shifting Tests A & B] | NS [Composite: Visual Verbal Word Learning Task Total Free Recall, Delayed Recall, Recognition] | 0 of 4 (no difference) | No adverse effects reported
Schiepers, 2009^111^ Margarines enriched with plant sterol esters (2.5 g/d) or plant stanol esters (2.5 g/d) n=57 1.6 years (85 weeks) | | | | NS [Complex Speed Composite: SCWT 3, Complex Shifting Test]
Schiepers, 2009^111^ Margarines enriched with plant sterol esters (2.5 g/d) or plant stanol esters (2.5 g/d) n=57 1.6 years (85 weeks) | | | | NS [DSST]
Omega 3 Multinutrient Results Summary k=1; n=27 | NR | NR | NR | 1 of 3 favor I k=1 | 1 of 3 favor I k=1 | 2 of 6 favor I | NR
Strike, 2016 ^121^ Efalex Active 50+ per day vs. placebo n=27 6 months | | | | I>C [CANTAB Motor Screening Task] | I>C [CANTAB VRM Immediate] | 2 of 6 favor I
| | | | NS [CANTAB Motor Screening Touch Accuracy] | NS [CANTAB VRM Delayed]
| | | | NS [Stockings of Cambridge] | NS [CANTAB PAL]
Omega-3 versus B Vitamins Results Summary k=1; n=884 | NR | NR | BCT 0 of 1 (no difference) k=1 MNP NR k=1 | NR | 0 of 2 (no difference) k=1 | 0 of 3 (no difference) | NR
Andreeva, 2011^101^ Omega-3 + B vitamins (folate, B_6_, B_12_) vs. B vitamins (folate, B_6_, B_12_) n=884 4 years | | | BCT NS [TICS-m] | | NS [TICS-m Memory] | 0 of 3 (no difference) | NR
Andreeva, 2011^101^ Omega-3 + B vitamins (folate, B_6_, B_12_) vs. B vitamins (folate, B_6_, B_12_) n=884 4 years | | | | | NS [TICS-m Recall]

a Decrease of 3 or more MMSE points or, if missing, incidence of cognitive decline or dementia.

b Decrease of 5 or more MMSE points or, if missing, incidence of cognitive decline or dementia.

c Composite: CVLT sum of words recalled, CVLT delayed recall, prospective memory test 1, prospective memory test 2, story recall, story recall delayed, verbal fluency, letter cancellation, location memory, location memory delayed, symbol-letter substitution, digit span forward & backward, simple reaction time, choice reaction time]

Shading indicates summary rows and columns.

3MS=Modified Mini Mental Status Examination; AD=Alzheimer’s disease; ADAS-Cog=Alzheimer’s Disease Assessment Scale-Cognitive Subscale; Ads=adverse effects; AVLT=Auditory Verbal Learning Test; B_6_=vitamin B_6_; B_12_=vitamin B_12_; BCT=brief cognitive test performance; C=control; CANTAB=Cambridge Nueropsychological Test Automated Battery; CANTAB PAL=Cambridge Nueropsychological Test Automated Battery Paired Associated Learning Test; CATD=clinical Alzheimer’s-type dementia; CDR=Clinical Dementia Rating; CERAD= Consortium to Establish a Registry for Alzheimer’s Disease; CHD=coronary heart disease; CVLT=California Verbal Learning Test; DHA=docosahexaenoic acid; DS=Digit Span (Forward and/or Backward); DSST=Digit Symbol Substitution; EPA=eicosapentaenoic acid; F-TICS=French version, Telephone Interview Cognitive Status; g/d=grams per day; HC=hippocampus; I=intervention; k=number of studies included; MCI=mild cognitive impairment; mg/d=milligrams per day; MMSE=Mini-Mental State Examination; MNP=multidomain neuropsychological test performance; MRI=magnetic resonance imaging; n=sample size; NR=not reported; NS=no statistically significant difference; PRM=Pattern Recognition Memory; RCFT=Rey-Osterrieth Complex Figure Test; RT=reaction time; SCWT=Stroop Color Word Test; SDMT=symbol digit modalities test; SWM=Spatial Working Memory; TIA=transient ischemic attack; TICS=Telephone Interview Cognitive Status; VRM=Verbal Recognition Memory; WAIS=Wechsler Adult Intelligence Scale;

### Omega-3 Versus Placebo

Seven RCTs with low to medium risk of bias enrolling a total of 21,027 adults compared some form of omega-3 fatty acids versus placebo in adults.^101, 103, 107, 115, 117, 119, 120^ Total sample sizes ranged from 65 to 11,685. Yurko-Mauro et al. used only docosahexaenoic acid (DHA),^119^ all others used some combination of eicosapentaenoic acid (EPA) plus DHA. Geleijnse et al. also used alpha-linolenic acid (ALA) as another omega-3 study arm.^107^ Only the ORIGIN study (n=15,077) allowed adults already using omega-3 supplementation to participate in the study.^120^ All studies assessed baseline cognition; six reported baseline Mini-Mental State Examination (MMSE) score of at least 28^103, 107, 115, 117, 119, 120^ while one study used the Isaacs Set Test (35.8).^101^ However, only three studies specified a baseline cognition inclusion criterion.^103, 115, 119^ Populations studied included adults with diabetes or impaired glucose tolerance,^120^ a history or ischemic heart disease,^101^ coronary patients,^107^ or healthy adults.^103, 115, 117, 119^

No study reported incident diagnosis of dementia or MCI as determined solely by clinical diagnosis. The ORIGIN study, a large multinational study of adults with diabetes or impaired glucose tolerance, used a combination of clinical diagnosis or an MMSE score less than 24 and found no difference in probable dementia incidence between EPA+DHA or placebo groups for the median duration of 6.2 years (HR 0.93 [0.86 to 1.0]).^120^

Overall, the studies provide low-strength evidence suggesting that omega-3 fatty acids do not improve cognitive performance between adults with normal cognition as compared to placebo. None of four studies (n=16,431) found a statistical improvement in brief cognitive test performance, such as the MMSE;^101, 107, 119, 120^ likewise, one study that assessed multidomain neuropsychological performance using a global composite also found no statistical difference between groups.^103^ Of 32 tests to assess executive function in five studies (n=5,079), 29 tests did not find a significant difference between groups, with a maximum followup of 6 years.^103, 115, 117, 119, 120^ The two tests with significant differences that favored the omega-3 fatty acid group were based on 548 participants and for only a 6 month followup.^117, 119^ Similarly, of 25 tests to assess memory in five studies (n=3,428),^101, 103, 115, 117, 119^ 22 did not find a significant difference between groups, with a maximum followup of 4 years. The three tests with the omega-3 fatty acid group performing better than the placebo group were from a single 6-month study that used six memory tests (n=483).^119^

No studies found significant differences in adverse events for omega-3 supplementation.

Four studies examined the effects of the omega-3 fatty acid interventions versus placebo on several subgoups. No significant differences in effect were found for age,^101, 107, 115, 120^ sex,^107, 115, 120^ or inclusion criteria disease condition.^107, 120^

Andreeva et al. used a 2X2 factorial design, assigning adults with a history of ischemic heart disease to four groups: placebo, omega-3, B vitamins (folate, B_6_, B_12_), or omega-3 plus B vitamins.^101^ Results noted above collapsed the four arms into one group with any omega-3 assignment versus one group without omega-3 assignment. Results when comparing the omega-3 alone group with the B vitamins alone group also found no significant differences between groups for any outcome. Likewise, the omega-3 plus B vitamins versus B vitamins alone did not result in significant differences between groups.

### Ginkgo Biloba Extract

Three randomized controlled trials (RCTs) (four publications) with low to medium risk of bias enrolling a total of 5,559 older adults with presumed normal cognition compared 240 mg/day of ginkgo biloba versus placebo in adults.^104, 105, 113, 116^ Total sample sizes ranged from 118 to 3,069. All studies assessed baseline cognition, two reporting baseline MMSE scores of at least 27.6^105, 116^ while one reported baseline Modified Mini-Mental State Examination (3MS) of 93 and Alzheimer’s Disease Assessment Scale-Cognitive Subscale (ADAS-Cog) of 6.5.^104, 113^ All studies specified a baseline cognition inclusion criterion.^103, 115, 119^ Age inclusion criterion were ≥70,^116^ ≥75,^104, 113^ and ≥85.^105^

Two studies provide low-strength evidence suggesting that ginkgo biloba does not affect incidence of probable CATD compared to placebo.^104, 113, 116^ Both studies assessed probable CATD according to Diagnostic Statistical Manual of Mental Disorders Fourth Edition (DSM-IV) criteria by adjudication panels of clinical experts.

Overall the studies also provide low-strength evidence that ginkgo biloba does not improve cognitive performance as compared to placebo. One study that assessed multidomain neuropsychological performance using the 3MS and the ADAS-Cog found no statistical difference between groups.^113^ Likewise, no differences between groups were found in either executive function^113^ or memory.^105, 113^

All studies reported adverse events. No studies found significant differences in adverse events for omega-3 supplementation. The two larger studies found no differences in adverse events between groups (n=5,437).^104, 113, 116^ Dodge et al., who recruited 122 adults 85 years and older with normal cognition, reported a larger number of strokes and transient ischemic attacks (TIA) in the gingko biloba group over 3.5 years (7 vs. 0, p=.01).^105^ However, the larger study by Vellas et al. (n=2,820) found no significant differences between groups in stroke, hemorrhagic events, and cardiac disorders over 5 years.

Two studies explored the effects of the ginkgo biloba interventions versus placebo on several subgoups. Vellas et al. found differences in effect in men, people who consumed alcohol at baseline, and adults who continued the intervention for at least four years.^116^ The authors also advised caution in interpreting the results since they assessed 13 planned subgroups (including age, APOE-4, MMSE ≤27 at baseline, hypertension, diabetes, hypercholesterolemia, body mass index (BMI) ≥27, and failing leg balance test) and did not adjust for multiple testing (all 3 groups showing differences would have been nonsignificant with a Bonferroni correction).^116^ In contrast, the GEM study did not find significant effect modification for sex. They also did not find differences for age, sex, race, APOE-E4 status, education, or MCI at baseline. However, CVD at baseline did show a significant treatment by group interaction (p=.02).

### Other Nutraceuticals

Three additional RCTs examined the effects of nutraceuticals on cognition. Resveratrol, a member of a group of plant compounds called polyphenols with possible antioxidant properties, was examined in one study. In this 6-month study on the use of resveratrol in 46 healthy overweight people aged 50–80 years, people assigned to resveratrol performed better on 2 of 6 memory tests and showed significant increases in functional connectivity of the hippocampus to frontal, parietal, and occipital areas of the brain when compared to placebo.^118^ No significant changes between groups in total gray matter volume or in the volume or microstructure of the hippocampus were noted.

Schiepers et al. (n=57) compared cognition in 57 adults assigned to consume margarines enriched with plant sterol or stanol esters with those using a control margarine and found after 85 weeks no differences between groups.^111^

Strike et al. (n=27) examined a commercial supplement containing 1 g DHA, 160 mg EPA, 240 mg ginkgo biloba, 60 mg phosphatidylserine, 20 mg vitamin E, 1 mg folic acid, and 20 mcg vitamin B_12_ per day versus placebo.^121^ The authors hypothesized the combination would provide a synergistic effect. After 6 months, the intervention group improved compared to the control group in one out of three executive function/attention/processing speed outcomes and one out of three memory tests.

No adverse effects were reported in any study. Due to the evidence base of single studies with small sample sizes (n<500), strength of evidence was not assessed for these three interventions.

## Adults With MCI

### Nutraceuticals Versus Inactive Control

Three RCTs compared nutraceuticals to inactive controls in older adults with MCI.^104, 106, 108^ Summaries of study results are detailed in Table 4C.3.

Table 4C.3 Results overview: Nutraceutical interventions in adults with MCI

Author Year Comparison N=Follow-up | Diagnosis | Biomarkers [specific biomarker] | Brief Cognitive Test Performance/Multidomain Neuropsychological Test Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
Omega-3 Results Summary k=1; n=36 | NR | NR | 0 of 1 (no difference) k=1 | 1 of 3 favor I k=1 | 3 of 5 favor I k=1 | | No serious AEs reported
Lee, 2013^108^ Omega-3 fatty acids (DHA 430 mg and EPA 150 mg) daily n=36 1 year | | | BCT NS [MMSE] | NS [Composite: CLOX-1, DS Forward] | I>C [Composite: VR I, VR II, RAVLT – Immediate & Delayed Recall, DS Backward] | 4 of 9 favor I | No serious AEs reported
Lee, 2013^108^ Omega-3 fatty acids (DHA 430 mg and EPA 150 mg) daily n=36 1 year | | | | NS [DSST] | I>C [VR I]
Lee, 2013^108^ Omega-3 fatty acids (DHA 430 mg and EPA 150 mg) daily n=36 1 year | | | | I>C [DS Forward & Backward] | NS [VR II]
Lee, 2013^108^ Omega-3 fatty acids (DHA 430 mg and EPA 150 mg) daily n=36 1 year | | | | | NS [RAVLT, Immediate Recall]
Lee, 2013^108^ Omega-3 fatty acids (DHA 430 mg and EPA 150 mg) daily n=36 1 year | | | | | I>C [RAVLT, Delayed Recall]
Ginkgo Biloba Results Summary k=2; n=642 | 0 of 5 (no difference) k=1 | NR | NR | 2 of 2 favor I | NR k=1 | 2 of 2 favor I | NS k=1
Gavrilova, 2014 ^106^ Ginkgo biloba (240 mg) daily n=160 6 months | | | | I>C [TMT A] | | 2 of 2 favor I | No serious AEs reported
Gavrilova, 2014 ^106^ Ginkgo biloba (240 mg) daily n=160 6 months | | | | I>C [TMT B]
DeKosky, 2008 ^104^ Ginkgo biloba extract 120 mg twice daily n=482 (MCI sub-sample) Median 6.1 years | NS [All Dementia] | | | | | | Serious AEs reported (NS):
DeKosky, 2008 ^104^ Ginkgo biloba extract 120 mg twice daily n=482 (MCI sub-sample) Median 6.1 years | NS [CATD Without Vascular Dementia] | | | | | | death, bleeding, CHD, stroke.
DeKosky, 2008 ^104^ Ginkgo biloba extract 120 mg twice daily n=482 (MCI sub-sample) Median 6.1 years | NS [CATD With Vascular Dementia]
DeKosky, 2008 ^104^ Ginkgo biloba extract 120 mg twice daily n=482 (MCI sub-sample) Median 6.1 years | NS [Total AD]
DeKosky, 2008 ^104^ Ginkgo biloba extract 120 mg twice daily n=482 (MCI sub-sample) Median 6.1 years | NS [Vascular Dementia Without CATD]

AD=Alzheimer’s disease; AE=adverse event; BCT=brief cognitive test performance; C=control; CATD: clinical Alzheimer’s-type dementia; CHD=coronary heart disease; CLOX-1=Clock Drawing Test; DHA=docosahexaenoic acid; DS=Digit Span (Forward and/or Backward); DSST=Digit Symbol Substitution Test; EPA=eicosapentaenoic acid; I=intervention; k=number of studies included; MMSE=Mini-Mental State Examination; n=sample size; MCI=mild cognitive impairment; mg=milligrams; MMSE=Mini-Mental State Examination; NR=not reported; NS=no statistically significant difference; RAVLT=Rey Auditory Verbal Learning Test; RCT: randomized controlled trial; TMT=Trails Making Test (A & B); VR=visual reproduction

Shading indicates summary rows and columns.

Lee et al. (n=36) examined the effects of daily omega-3 fatty acids (fish oil supplementation, DHA 430 mg and EPA 150 mg) on cognitive function in people aged 60 and older with MCI.^108^ After 1 year, no significant change in MMSE scores was observed. However, people taking omega-3 performed better than those on placebo on one of three tests of executive function/attention/processing speed, and better on three of five memory tests. No serious adverse effects were reported. Evidence to draw conclusions was insufficient due to limited data (single study with n<500) or no data.

Two (2) studies compared the effects of ginkgo biloba to placebo in people with MCI.^104, 106^ Follow-up periods in the studies varied, with Gavrilova’s study lasting 6 months^81^ and median follow-up in DeKosky et al. lasting 6.1 years.^79^

DeKosky et al. examined diagnostic outcomes.^104^ Of five categories of dementia, no significant differences were found between ginkgo and placebo groups. Gavrilova et al. included two objective measures of cognition, both related to the executive function/attention/processing speed domain. In both tests, participants taking ginkgo performed significantly better than those taking placebo.^106^

Gavrilova et al. reported no serious adverse effects.^106^ DeKosky et al. found no significant differences between ginkgo and placebo groups in rates of serious adverse effects, including death, bleeding, coronary heart disease (CHD), and stroke.^104^ Evidence to draw conclusions was insufficient due to limited data (single study with n<500) or no data.

## Interpreting the Findings

The results show no benefit for the nutraceuticals that have been examined. Some nutraceuticals, such as resveratrol, have not been studied enough to provide sufficient evidence from which to draw conclusions. Most nutraceuticals are based on doses an individual could derive from diet, and are hypothesized to be much less likely to have adverse effects than “therapeutic” doses. However, this also means the interactions with metabolic, environmental, and other nutrition intake may overwhelm possible small effects related to nutritional doses. Designing studies to take such complexity into account is challenging.

* Note that the literature currently does not use the term CATD; we specified whenever the diagnosis of dementia was defined.