# 4B Results: Physical Activity Interventions

## Key Messages

- Studies of physical activity interventions examined a wide variety of activities potentially targeting different pathways to affect cognition.
- Evidence is insufficient to conclude whether physical activity interventions prevent mild cognitive impairment (MCI) or clinical Alzheimer’s-type dementia (CATD)^*^ incidence.
- Low-strength evidence shows that multicomponent physical activity interventions offer no clear benefit in cognitive performance over attention control in adults with normal cognition.
- Evidence was insufficient to conclude whether other types of physical activity interventions had benefits for cognitive outcomes in adults with normal cognition.
- While the majority of results showed no significant difference, the pattern of results across very different types of physical activity interventions provides an indication of effectiveness of physical activity.

## Eligible Studies

We identified 48 eligible publications reporting 43 unique studies of physical activity interventions to prevent age-related cognitive decline, MCI, or CATD.^43, 54–100^ Twenty-four were assessed as high risk of bias and not used in our analysis, leaving 19 publications for analysis. We analyzed the efficacy and comparative effectiveness of physical activity interventions separately for adults with normal cognition and those with MCI. Appendix G provides evidence tables, summary risk of bias assessments, and assessments of strength of evidence for key comparisons and outcomes.

## Logic of Physical Activity Interventions

Many observational studies and systematic reviews have identified a correlation between physically active lifestyles and decreased rates of CATD. Generally, the selection bias inherent in observational studies precludes adequate testing of correlations for causal relationships; however, experimental studies designed to test the nature of the correlation between physical activity and reduced dementia risk suggest potential mechanisms of action justifying a potential causal relationship. Many justify the relationship by citing previous research. Authors only sometimes proposed mechanisms of action, which included enhanced blood flow and neuronal connectivity,^80, 91^ increased brain volume,^80, 91, 100^ potential reductions in β-amyloid deposition,^91^ reductions in chronic disease risk,^54, 95^ anxiety and depression (which are associated with cognitive function), and lowered blood viscosity (which improves aerobic capacity and cognition).^54^

## Adults With Normal Cognition

### Efficacy: Physical Activity Versus Inactive Control

Twelve randomized controlled trials (RCTs) reported in eight publications with low to medium risk of bias compared physical activity interventions to inactive controls in adults with normal cognition.^54, 60, 71, 80, 83, 85, 86, 89, 91, 95, 97, 100^ Total sample sizes ranged from 42 to 1,635. Four studies examined multicomponent physical activity interventions.^83, 91, 95, 100^ Single component physical activity interventions consisted of resistance training,^60, 71, 97^ aerobic exercise/endurance,^54, 74, 80, 85, 86, 89^ and Tai Chi.^95^ Inactive comparisons included usual care, information, and/or attention controls (i.e., health education). Results are presented by type of physical activity intervention. Conclusions are summarized in Table 4B.1 and individual study results in Table 4B.2.

Table 4B.1 Conclusions: Physical activity versus inactive comparisons in adults with normal cognition

Comparison | Outcome | Conclusion | Strength of Evidence (justification)
Multicomponent physical activity vs. attention control k=4 | Dementia | Unable to draw conclusion. | Insufficient (medium study limitations, imprecise, unknown consistency)
Multicomponent physical activity vs. attention control k=4 | MCI | Unable to draw conclusion. | Insufficient (medium study limitations, imprecise, unknown consistency)
Multicomponent physical activity vs. attention control k=4 | Brief cognitive test performance | No benefit in brief cognitive test performance with multicomponent physical activity versus attention control (n=155; 6 months to 1 year). | Insufficient (medium study limitations, indirect, imprecise, inconsistent)
Multicomponent physical activity vs. attention control k=4 | Multidomain neuropsychological performance | No benefit in multidomain neuropsychological performance with multicomponent physical activity versus attention control (n=1,635; 2 years). | Low (medium study limitations, indirect, unknown consistency)
Multicomponent physical activity vs. attention control k=4 | Executive/Attention/Processing speed | No benefit in executive/attention/processing speed with multicomponent physical activity versus attention control (n=1,885; 6 months to 1 year). | Low (medium study limitations, indirect, imprecise)
Multicomponent physical activity vs. attention control k=4 | Memory | No benefit in memory with multicomponent physical activity versus attention control (n=1,836; 6 months to 1 year). | Low (medium study limitations, indirect, imprecise)
Resistance training vs. attention control k=3 | Dementia | No data available. | Insufficient (no data)
Resistance training vs. attention control k=3 | MCI | No data available. | Insufficient (no data)
Resistance training vs. attention control k=3 | Brief cognitive test performance | No data available. | Insufficient (no data)
Resistance training vs. attention control k=3 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
Resistance training vs. attention control k=3 | Executive/Attention/Processing speed | No benefit in executive/attention/processing speed with resistance training versus attention control (n=120; 6 months). | Insufficient (medium study limitations, indirect, imprecise, inconsistent)
Resistance training vs. attention control k=3 | Memory | No benefit in brief cognitive test performance with resistance training versus attention control (n=172; 6 months). | Insufficient (medium study limitations, indirect, imprecise, inconsistent)
Aerobic training vs. attention control k=6 | Dementia | Limited data. | Insufficient (limited data)
Aerobic training vs. attention control k=6 | MCI | No data available. | Insufficient (no data)
Aerobic training vs. attention control k=6 | Brief cognitive test performance | No benefit in brief cognitive test performance with aerobic training interventions (n=162; 6 months to 1 year). | Insufficient (medium study limitations, indirect, imprecise)
Aerobic training vs. attention control k=6 | Multidomain neuropsychological performance | Limited data. | Insufficient (limited data)
Aerobic training vs. attention control k=6 | Executive/Attention/Processing speed | Unable to draw conclusion. | Insufficient (medium study limitations, indirect, imprecise, inconsistent)
Aerobic training vs. attention control k=6 | Memory | Unable to draw conclusion | Insufficient (medium study limitations, indirect, imprecise, inconsistent)
Tai Chi vs. attention control k=1 | Dementia | No data available. | Insufficient (no data)
Tai Chi vs. attention control k=1 | MCI | No data available. | Insufficient (no data)
Tai Chi vs. attention control k=1 | Brief cognitive test performance | No data available. | Insufficient (no data)
Tai Chi vs. attention control k=1 | Multidomain neuropsychological performance | No data available. | Insufficient (no data)
Tai Chi vs. attention control k=1 | Executive/Attention/Processing speed | Limited data. | Insufficient (limited data)
Tai Chi vs. attention control k=1 | Memory | No data available. | Insufficient (no data)

k=number of studies included; MCI=mild cognitive impairment; n=sample size; vs.=versus

Table 4B.2 Results overview: Physical activity versus inactive comparisons in adults with normal cognition

Author Year Comparison N= Followup | Diagnosis | Biomarkers [specific biomarker] | Brief Cognitive Test Performance/Multidomain Neuropsychological Test Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
Multicomponent Physical Activity Results Summary k=4; n=1,885 | 0 of 3 (no difference) k=1 | NR | BCT 1 of 2 favors I k=2 MNP 0 of 1 (no difference) k=1 | 1 of 13 favor I k=4 | 1 of 6 favor I k=3 | 3 of 25 favor I | NR
Sink, 2015^91^ Multicomponent physical activity vs. attention control n=1,635 2 years | NS [Dementia] | | | NS [DSST] | NS [HVLT, Immediate Recall] | 1 of 15 favor I | NR
Sink, 2015^91^ Multicomponent physical activity vs. attention control n=1,635 2 years | NS [MCI] | | MNP NS [Global Composite^a^] | NS [N-Back, 1 back] | NS [HVLT, Delayed Recall]
Sink, 2015^91^ Multicomponent physical activity vs. attention control n=1,635 2 years | NS [Dementia or MCI] | | | NS [N-Back, 2 back] | NS [HVLT, Composite^b^]
Sink, 2015^91^ Multicomponent physical activity vs. attention control n=1,635 2 years | | | | NS [RT on Task Switching, No]
Sink, 2015^91^ Multicomponent physical activity vs. attention control n=1,635 2 years | | | | NS [RT on task switching, Yes]
Sink, 2015^91^ Multicomponent physical activity vs. attention control n=1,635 2 years | | | | I>C [RT on Flanker Test, Congruent]
Sink, 2015^91^ Multicomponent physical activity vs. attention control n=1,635 2 years | | | | NS [RT on Flanker Test, Incongruent]
Sink, 2015^91^ Multicomponent physical activity vs. attention control n=1,635 2 years | | | | NS [Composite of Flanker test scores^c^]
Napoli, 2014^83^ Multicomponent physical activity vs. attention control n=53 1 year | | | BCT I>C [3MS] | NS [TMT A] | I>C [Word List Fluency] | 2 of 4 favor I | NR
Napoli, 2014^83^ Multicomponent physical activity vs. attention control n=53 1 year | | | | NS [TMT B]
Taylor-Piliae, 2010^95^ I_1_ Multicomponent physical activity vs. attention control n=95 6 months | | | | NS [DS Forward] | | 0 of 2 (no difference) | NR
Taylor-Piliae, 2010^95^ I_1_ Multicomponent physical activity vs. attention control n=95 6 months | | | | NS [DS Backward]
Williamson, 2009^100^ Multicomponent physical activity vs. attention control n=102 1 year | | | BCT NS [3MS] | NS [SCWT] | NS [RAVLT] | 0 of 4 (no difference) | NR
Williamson, 2009^100^ Multicomponent physical activity vs. attention control n=102 1 year | | | | | NS [DSST]
Resistance Training Results Summary k=3; n=170 | NR | NR | NR | 8 of 25 favor I k=3 | 3 of 11 favor I k=1 | 11 of 36 favor I | NR
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=55 6 months | | | | I>C [DS Forward] | NS [Word Learning Test, Immediate Recall-75 Words] | 2 of 17 favor I | NR
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=55 6 months | | | | NS [DS Backward] | NS [Word Learning Test, Delayed Recall-15 Words]
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=55 6 months | | | | NS [TMT A] | NS Word Learning Test, Decay]
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=55 6 months | | | | NS [Stroop 1] | NS [Word Learning Test, Recognition, 30 Words]
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=55 6 months | | | | NS [Stroop 2] | I>C^z^ [Attention and Working Memory Composite]
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=55 6 months | | | | NS [Stroop Inference] | NS^z^ [Episodic Memory Composite]
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=55 6 months | | | | NS [RT Uncued]
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=55 6 months | | | | NS [RT Cued]
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=55 6 months | | | | NS [Word Fluency-Letter]
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=55 6 months | | | | NS^z^ [Processing Speed Composite]
van de Rest, 2014^97^ Resistance-type exercise program vs. usual care n=55 6 months | | | | NS^z^ [Executive Functioning Composite]
Cassilhas, 2007^60^ High resistance training (I_1_) vs. attention control n=43 males 6 months | | | | I_1_>C [DS Forward] | NS [RCFT, Copy] | 5 of 9 favor I | NR
Cassilhas, 2007^60^ High resistance training (I_1_) vs. attention control n=43 males 6 months | | | | NS [DS Backward] | I_1_>C [RCFT, Immediate Recall]
Cassilhas, 2007^60^ High resistance training (I_1_) vs. attention control n=43 males 6 months | | | | NS [Corsi Block, Forward]
Cassilhas, 2007^60^ High resistance training (I_1_) vs. attention control n=43 males 6 months | | | | I_1_>C [Corsi Block, Backward]
Cassilhas, 2007^60^ High resistance training (I_1_) vs. attention control n=43 males 6 months | | | | I_1_>C [Corsi Block, Similarities]
Cassilhas, 2007^60^ High resistance training (I_1_) vs. attention control n=43 males 6 months | | | | NS [Toulouse-Pieron, Cancellations Numbers]
Cassilhas, 2007^60^ High resistance training (I_1_) vs. attention control n=43 males 6 months | | | | I_1_>C [Toulouse-Pieron, Errors]
Cassilhas, 2007^60^ Moderate resistance training (I_2_) vs. attention control n=42 males 6 months | | | | I_2_>C [DS Forward] | NS [RCFT, Copy] | 4 of 9 favor I | NR
Cassilhas, 2007^60^ Moderate resistance training (I_2_) vs. attention control n=42 males 6 months | | | | NS [DS Backward] | I_2_>C [RCFT, Immediate Recall]
Cassilhas, 2007^60^ Moderate resistance training (I_2_) vs. attention control n=42 males 6 months | | | | NS [Corsi Block, Forward]
Cassilhas, 2007^60^ Moderate resistance training (I_2_) vs. attention control n=42 males 6 months | | | | I_2_>C [Corsi Block, Backward]
Cassilhas, 2007^60^ Moderate resistance training (I_2_) vs. attention control n=42 males 6 months | | | | I_2_>C [Corsi Block, Similarites]
Cassilhas, 2007^60^ Moderate resistance training (I_2_) vs. attention control n=42 males 6 months | | | | NS [Toulouse-Pieron, Cancellations Numbers]
Cassilhas, 2007^60^ Moderate resistance training (I_2_) vs. attention control n=42 males 6 months | | | | NS [Toulouse-Pieron, Errors]
Lachman, 2006^71^ Resistance training vs. waitlist n=52 | | | | | NS [DS Backward]
Aerobic Training Results Summary k=6; n=531 | 1 of 1 favors I k=1 | NR | BCT 1 of 3 favor I k=2 MNP 1 of 1 favor I k=1 | 3 of 14 favor I k=3 | 6 of 18 favor I k=5 | 10 of 21 favor I | 0 of 3 (no difference) (k=1)
Antunes, 2015^54^ Multicomponent physical activity vs. usual care n=46 older males 6 months | | | | I>C [Picture Arrangement, WAIS-III] | NS [Verbal Paired Associates, Trial 1, Easy Pair] | 7 of 16 favor I
Antunes, 2015^54^ Multicomponent physical activity vs. usual care n=46 older males 6 months | | | | I>C [Corsi Block-tapping, Forward] | I>C [Verbal Paired Associates, Trial 1, Hard Pair]
Antunes, 2015^54^ Multicomponent physical activity vs. usual care n=46 older males 6 months | | | | NS [Corsi Block-tapping, Backward] | NS [Verbal Paired Associates, Trial 2, Easy Pair]
Antunes, 2015^54^ Multicomponent physical activity vs. usual care n=46 older males 6 months | | | | | I>C [Verbal Paired Associates, Trial 2, Hard Pair]
Antunes, 2015^54^ Multicomponent physical activity vs. usual care n=46 older males 6 months | | | | | NS [Verbal Paired Associates, Trial 3, Easy Pair]
Antunes, 2015^54^ Multicomponent physical activity vs. usual care n=46 older males 6 months | | | | | I>C Memory [Verbal Paired, Trial 3, Hard Pair]
Antunes, 2015^54^ Multicomponent physical activity vs. usual care n=46 older males 6 months | | | | | NS [Verbal Paired Associates, Recall Test, Easy Pair]
Antunes, 2015^54^ Multicomponent physical activity vs. usual care n=46 older males 6 months | | | | | NS [Verbal Paired Associates, Recall Test, Hard Pair]
Antunes, 2015^54^ Multicomponent physical activity vs. usual care n=46 older males 6 months | | | | | I>C [Free Word Recall. Total Words Recalled (Non-Semantic)]
Antunes, 2015^54^ Multicomponent physical activity vs. usual care n=46 older males 6 months | | | | | I>C [Free Word Recall, Total Words Recalled (Semantic)]
Antunes, 2015^54^ Multicomponent physical activity vs. usual care n=46 older males 6 months | | | | | NS [Free Word Recall, Intrusions]
Antunes, 2015^54^ Multicomponent physical activity vs. usual care n=46 older males 6 months | | | | | Unclear [Free Word Recall, Repetitions]
Antunes, 2015^54^ Multicomponent physical activity vs. usual care n=46 older males 6 months | | | | | Unclear [Free Word Recall, Preservations]
Ruscheweyh 2011^89^ Gymnastics vs.no intervention n=42 6 months | | | | | NS [RAVLT-German] | 0 of 1 (no difference)
Ruscheweyh 2011^89^ Nordic walking vs. no intervention n=41 6 months | | | | | NS [RAVLT-German] | 0 of 1 (no difference)
Muscari, 2010^80^ Endurance training vs. information control n=120 1 year | | | BCT I>C [MMSE] | | | 1 of 1 favor I | NR
Lautenschlager, 2008^74^ Home-based physical activity vs. information control n=170 6 months | | | MNP I>C [ADAS-Cog] | NS [DSST] | NS [Word List, Immediate Recall] | 3 of 5 favor I | NS [Cardiovascular problem] NS [Stroke] NS [Shoulder operation]
Lautenschlager, 2008^74^ Home-based physical activity vs. information control n=170 6 months | I>C [Clinical Dementia Rating, Sum of Boxes (diagnosis estimate)] | | | | I>C [Word List, Delayed Recall] | | NS [Cardiovascular problem] NS [Stroke] NS [Shoulder operation]
Oken 2006^85^ Aerobic exercise vs. waitlist control n=91 6 months | | | | NS [SCWT Inference] | NS [Word List, Delayed Recall] | 0 of 9 (no difference)
Oken 2006^85^ Aerobic exercise vs. waitlist control n=91 6 months | | | | NS [Covert Orienting (Invalid-Valid)] | NS [Letter-Number Sequencing]
Oken 2006^85^ Aerobic exercise vs. waitlist control n=91 6 months | | | | NS [Divided Attention]
Oken 2006^85^ Aerobic exercise vs. waitlist control n=91 6 months | | | | NS [% Errors Above Threshold]
Oken 2006^85^ Aerobic exercise vs. waitlist control n=91 6 months | | | | NS [Set Shifting: Highest Shift]
Oken 2006^85^ Aerobic exercise vs. waitlist control n=91 6 months | | | | NS [Simple RT]
Oken 2006^85^ Aerobic exercise vs. waitlist control n=91 6 months | | | | NS [Choice RT]
Okumiya 1996^86^ Aerobic exercise program vs. no program n=42 6 months | | | BCT NS [MMSE] | | | 0 of 2 (no difference)
Okumiya 1996^86^ Aerobic exercise program vs. no program n=42 6 months | | | BCT NS [Hasegawa Dementia Scale]
Tai Chi Results Summary k=1; n=93 | NR | NR | NR | 1 of 2 favor I (k=1) | NR | NR | NR
Taylor-Piliae, 2010^95^ I_2_ Tai Chi vs. attention control n=93 6 months | | | | I_2_>C [DS Backward] | | 1 of 2 favor I_2_ | NR
Taylor-Piliae, 2010^95^ I_2_ Tai Chi vs. attention control n=93 6 months | | | | NS [DS Forward]
Taylor-Piliae, 2010^95^ I_2_ Tai Chi vs. attention control n=93 6 months

a mean global composite z score composed of Digit Symbol Coding, HVLT immediate and delayed recall, n-back task, and reaction time on task switching and Flanker tasks;

b composite z score of HVLT-R immediate and delayed word recall;

c composite z score of Flanker congruent and incongruent reaction times. Shading indicates summary rows and columns.

3MS=Modified Mini-Mental State Examination; ADAS-Cog=Alzheimer’s Disease Assessment Scale-Cognitive Subscale; BCT=brief cognitive test performance; C=inactive control; DS=Digit Span (Forward or Backward); DSST=Digit Symbol Substitution Test; HVLT-R=Hopkins Verbal Learning Test-Revised; I=intervention; I_1_=first intervention; I_2_=second intervention; k=number of studies; MCI=mild cognitive impairment; MMSE=Mini-Mental State Examination; MNP=multidomain neuropsychological performance; n=sample size; NR=not reported; NS=no statistically significant difference; RAVLT=Rey Auditory Verbal Learning Test; RCFT=Rey-Osterrieth Complex Figure Test; RT=reaction time; SCWT=Stroop Color Word Test; TMT=Trail-Making Test (Parts A and/or B); vs.=versus; WAIS=Wechsler Adult Intelligence Scale

#### Multicomponent Physical Activity

Multicomponent physical activity interventions included flexibility, strength, balance, endurance, and/or aerobic components.^83, 91, 95, 100^ Enrollment criteria varied by trial. One trial enrolled sedentary adults over 70;^91, 100^ another enrolled adults over 60,^95^ and the last enrolled frail obese older adults.^83^

Only the large 2-year trial (n=1,635) reported diagnostic outcomes, finding no difference between multicomponent physical activity and attention control in diagnosis of MCI or CATD.^91^ Evidence was insufficient to conclude whether a multicomponent physical activity intervention prevents MCI or CATD over a 2-year time period when compared with attention control in adults with normal cognition.

Two trials (n=155) assessed cognition with brief cognitive tests.^83, 100^ After the intervention, one trial found no statistical difference between multicomponent physical activity and attention control in changes from baseline (n=102),^74^ and one (n=53) showed a statistically significant improvement in Modified Mini-Mental State Examination (3MS) scores.^64^ However, the difference in mean change from baseline between intervention and control was three points (95% CI: 1.5 to 4.5). The mean 3MS score in the control group remained nearly the same from baseline (96.3 of 100 possible) to 12 months and the mean score in the moderate physical activity group improved by nearly three points from baseline (94.9 of 100 possible). This three-point change is not likely clinically meaningful given that identified reliable change indices for this instrument range from 5 to 10 points. Evidence was insufficient to conclude whether multicomponent physical activity interventions with durations of 6 months to 1 year have an effect on brief cognitive test performance when compared to attention control in older sedentary adults.

The large 2-year trial (n=1,635) showed no statistical difference with multicomponent physical activity versus attention control in multidomain neuropsychological performance assessed using an investigator-created composite score.^91^ Low-strength evidence shows that a multicomponent physical activity intervention with duration of 2 years has no significant effect on multidomain neuropsychological performance when compared with attention control in older sedentary adults.

Four trials (n=1,885) used 13 tests to measure the effects of multicomponent physical activity on executive function/attention/processing speed.^83, 91, 95, 100^ Only one of the 13 tests showed a statistically significant improvement with multicomponent physical activity compared with attention control. Low-strength evidence shows that multicomponent physical activity interventions lasting 6 months to 2 years have no significant effect on executive function, attention, or processing speed when compared with attention control in older sedentary adults.

Three trials (n=1,890) reported results of six memory tests; only one test result showed a statistical difference favoring the intervention.^83, 91, 100^ Napoli et al. showed greater improvements from baseline with multicomponent physical activity than attention control.^83^ Participants improved their verbal fluency (naming animals) by a mean of over 4.1 with multicomponent physical activity, but decreased by 0.8 with attention control, for a mean difference of 4.9. This improvement is not likely clinically meaningful given an identified reliable change index of over 10. Low-strength evidence shows that multicomponent physical activity interventions lasting 6 months to 2 years have no significant effect on memory when compared to attention control in older sedentary adults.

No study of multicomponent physical activity interventions in adults with normal cognition reported other cognitive outcomes, biomarker measures, or adverse effects.

Sink et al. report subgroup effects by sex, age, baseline MMSE and baseline Short Physical Performance Battery scores.^91^ Subgroup effects were tested on four outcomes. Two instruments assessed three cognitive domains (executive function, processing speed, and verbal memory) and two composite scores assessed executive function and global cognitive function (according to authors). Physical activity led to better effects on the composite executive function score than health education (attention control) in participants aged 80 to 89. There were no other subgroup differences in executive function.

#### Resistance Training

Three studies compared resistance training to attention control or placebo.^60, 71, 97^ Van de Rest, et al. enrolled adults over 65;^97^ Cassilhas et al. enrolled sedentary men between 65 and 75;^60^ and Lachman et al. enrolled sedentary older adults with at least one disability.^71^ Cassilhas et al. randomized participants to one of three groups (attention control, high-resistance training, and low-resistance training). Lachman et al. randomized participants to the Strong for Life program or waitlist control.

Neither trial reported diagnoses or overall cognitive performance outcomes. Van de Rest reported 11 tests of executive function, attention, and processing speed and Cassilhas et al. reported seven (making comparison for each of the intervention groups to attention control).^60^ Evidence was insufficient to draw conclusions about the effects of resistance training on executive function/attention/processing speed or memory. Results were inconsistent. Eight of the 25 comparisons showed a statistically significant improvement in executive function/attention/processing speed with resistance training versus attention control or placebo. Only one of the eight comparisons tested in van de Rest et al. showed a statistically significant improvement with resistance training compared to placebo control.^97^ Cassilhas et al. showed improvements in four of seven tests of executive function, attention, and/or processing speed with high resistance training and three of seven tests of executive function, attention, and/or processing speed with moderate resistance training compared with attention control, scores on digit span, forward; Corsi’s block-tapping, backward; and similarities improved with high resistance training compared with attention control.^60^ Scores on digit span, forward; Corsi’s block-tapping, backward; and similarities improved with moderate resistance training compared with attention control.^60^

Van de Rest reported six measures of memory;^97^ Cassilhas et al. reported two;^60^ and Lachman et al. reported one.^71^ Van de Rest et al. showed no statistical differences between resistance training and attention control in any memory score.^97^ Cassilhas et al. showed improvements in one of two memory scores with resistance training; both high and moderate intensity resistance training improved compared with attention control.^60^ Lachman et al. showed no statistical difference on memory with resistance training versus waitlist control.^71^ Evidence was insufficient to draw conclusions about the effects of resistance training on memory.

None of the resistance training intervention studies reported adverse effects.

Van de Rest et al. examined the effect of frailty on the effect of resistance training on reaction time.^97^ Treatment-time interaction was not significant for any of the five reaction time measures compared.

#### Aerobic Activity

Six trials with low to medium risk of bias compared aerobic or endurance programs to an attention control.^54, 74, 80, 85, 86, 89^ Antunes et al. enrolled sedentary older men;^54^ Ruscheweyh et al. enrolled healthy older adults;^89^ Muscari et al. enrolled healthy older adults;^80^ Lautenschlager et al. enrolled adults having difficulty with memory and MMSE scores of 24 or greater;^74^ Oken et al. enrolled healthy older adults;^85^ Okumiya enrolled healthy older adults.^86^

Only Lautenschlager et al. reported dementia diagnosis outcomes and found that aerobic training was less likely to lead to a diagnosis than attention control.^74^ Evidence was insufficient to conclude whether aerobic training offers benefits related to preventing dementia.

Three trials reported either brief cognitive or multidomain neuropsychological test performance. Muscari et al. showed that brief cognitive test performance was better with aerobic training^80^ Oken et al. showed no statistical difference with aerobic exercise with two tests of brief cognitive test performance.^85^ Antunes et al. found that multidomain neuropsychological test performance was better with aerobic training.^54^ Evidence was insufficient to conclude whether aerobic training offers benefits related to brief cognitive or multidomain neuropsychological test performance.

Other domains of cognitive performance were also reported. Executive function/attention/processing speed were better with aerobic training in two of four tests and memory was better in six of 15 tests. Evidence was insufficient to conclude whether aerobic training offers benefits related to executive function, attention, and/or processing speed, or memory.

#### Tai Chi

One trial compared Tai Chi to an attention control.^95^ Executive function, attention, and/or processing speed were better with Tai Chi than with the attention control. Evidence was insufficient to conclude whether Tai Chi offers benefits related to executive function, attention, and/or processing speed.

### Comparative Effectiveness: Physical Activity Versus Active Comparison

Seven studies compared physical activity interventions to active interventions.^56, 60, 62, 83, 85, 89, 95^ Individual study results are provided in Table 4B.3. Eggenberger et al. (n=89) compared 6-months of virtual reality dance video game with treadmill walking combined with verbal memory training in adults over 70.^62^ Napoli et al. (n=54) compared exercise with an exercise and diet program.^83^ Baker et al. (n=34) compared 6-months of an aerobic exercise program with stretching.^56^ Taylor-Piliae et al. (n=132) compared multicomponent physical activity with Tai Chi.^95^ Cassilhas et al. (n=39) compared a high intensity resistance training with a lower intensity resistance training.^60^ Oken et al. (n=91) compared yoga to aerobic exercise.^85^ Ruscheweyh et al. (n=41) compared two types of aerobic activity, an aerobic exercise class with Nordic walking.^89^

Table 4B.3 Results overview: Physical activity versus active comparisons in adults with normal cognition

Author Year Comparison N= Followup | Diagnosis | Biomarkers [specific biomarker] | Brief Cognitive Test Performance/Multidomain Neuropsychological Test Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
Aerobic vs. Stretching/Toning/Yoga Results Summary k=2; n=125 | NR | NR | NR | 3 of 12 favor I_1_ k=2 | 0 of 3 favor I_1_ k=2 | 3 of 15 favor I_1_ | NR
Baker, 2010 ^56^ Aerobic exercise (I_1_) vs. stretching (I_2_) n=34 6 months | | | | I_1_>I_2_ [TMT B] | NR [Story Recall] | 3 of 7 favor I_1_ | NR
Baker, 2010 ^56^ Aerobic exercise (I_1_) vs. stretching (I_2_) n=34 6 months | | | | I_1_>I_2_ [Task Switching]
Baker, 2010 ^56^ Aerobic exercise (I_1_) vs. stretching (I_2_) n=34 6 months | | | | I_1_>I_2_ [SCWT Inference
Baker, 2010 ^56^ Aerobic exercise (I_1_) vs. stretching (I_2_) n=34 6 months | | | | NS [Self-Ordered Point Test]
Baker, 2010 ^56^ Aerobic exercise (I_1_) vs. stretching (I_2_) n=34 6 months | | | | NS [Verbal Fluency]
Oken 2006^85^ Yoga vs. aerobic exercise n=91 6 months | | | | NS [SCWT Inference] | NS [Word List, Delayed Recall] | 0 of 9 (no difference)
Oken 2006^85^ Yoga vs. aerobic exercise n=91 6 months | | | | NS [Covert Orienting (Invalid-Valid)] | NS [Letter-number sequencing, WAIS-III]
Oken 2006^85^ Yoga vs. aerobic exercise n=91 6 months | | | | NS [Divided Attention Threshold]
Oken 2006^85^ Yoga vs. aerobic exercise n=91 6 months | | | | NS [% Errors Above Threshold]
Oken 2006^85^ Yoga vs. aerobic exercise n=91 6 months | | | | NS [Set Shifting: Highest Shift]
Oken 2006^85^ Yoga vs. aerobic exercise n=91 6 months | | | | NS [Simple RT]
Oken 2006^85^ Yoga vs. aerobic exercise n=91 6 months | | | | NS [Choice RT]
Unique Comparisons | NA | NA | NA | NA | NA | NA | NA
Eggenberger, 2015^62^ Dance/treadmill memory training vs. treadmill n=89 6 months | | | | NS [TMT A] | NS [Story Recall] | 0 of 9 (no difference) | NR
Eggenberger, 2015^62^ Dance/treadmill memory training vs. treadmill n=89 6 months | | | | NS [TMT B] | NS [Paired Associates Learning]
Eggenberger, 2015^62^ Dance/treadmill memory training vs. treadmill n=89 6 months | | | | NS [Executive Control Task]
Eggenberger, 2015^62^ Dance/treadmill memory training vs. treadmill n=89 6 months | | | | NS [DS Forward]
Eggenberger, 2015^62^ Dance/treadmill memory training vs. treadmill n=89 6 months | | | | NS [Age Concentration Test A]
Eggenberger, 2015^62^ Dance/treadmill memory training vs. treadmill n=89 6 months | | | | NS [Age Concentration Test B]
Eggenberger, 2015^62^ Dance/treadmill memory training vs. treadmill n=89 6 months | | | | NS [DSST]
Napoli, 2014^83^ I_1_ Exercise vs. I_2_ diet + exercise n=54 1 year | | | BCT NS [3MS] | NS [TMT A] | NS [Word List Fluency] | 0 of 4 favor (no difference) | NR
Napoli, 2014^83^ I_1_ Exercise vs. I_2_ diet + exercise n=54 1 year | | | | NS [TMT B]
Ruscheweyh 2011^89^ Nordic walking vs. gymnastics n=41 6 months | | | | | NS [AVLT] | 0 of 1 (no difference)
Taylor-Piliae, 2010^95^ I_1_ Multicomponent physical activity vs. I_2_ Tai Chi n=70 | | | | I_2_>I_1_ [DS Backward] | | 1 of 2 favor I_2_
Taylor-Piliae, 2010^95^ I_1_ Multicomponent physical activity vs. I_2_ Tai Chi n=70 | | | | NS [DS Forward]
Cassilhas, 2007^60^ High resistance training (I_1_) vs. Moderate resistance training (I_2_) n=39 6 months | | | | NS [DS Forward] | NS [RCFT, Copy] | 0 of 9 (no difference) | NR
Cassilhas, 2007^60^ High resistance training (I_1_) vs. Moderate resistance training (I_2_) n=39 6 months | | | | NS [DS Backward] | NS [RCFT, Immediate Recall]
Cassilhas, 2007^60^ High resistance training (I_1_) vs. Moderate resistance training (I_2_) n=39 6 months | | | | NS [Corsi Block, Forward]
Cassilhas, 2007^60^ High resistance training (I_1_) vs. Moderate resistance training (I_2_) n=39 6 months | | | | NS [Corsi Block, Backward]
Cassilhas, 2007^60^ High resistance training (I_1_) vs. Moderate resistance training (I_2_) n=39 6 months | | | | NS [Corsi Block, Similarites]
Cassilhas, 2007^60^ High resistance training (I_1_) vs. Moderate resistance training (I_2_) n=39 6 months | | | | NS [Toulouse-Pieron, Cancellations Numbers]
Cassilhas, 2007^60^ High resistance training (I_1_) vs. Moderate resistance training (I_2_) n=39 6 months | | | | NS [Toulouse-Pieron, Errors]

AVLT=Auditory Verbal Learning Test; C=inactive control; DS=Digit Span (Forward and/or Backward); DSST=Digit Symbol Substitution Test; I=intervention; I_1_=first intervention; I_2_=second intervention; k=number of studies; n=sample size; NR=not reported; NS=no statistically significant difference; RCFT=Rey-Osterrieth Complex Figure Test; RT=reaction time; SCWT=Stroop Color Word Test; TMT=Trail Making Test (A and/or B) vs.=versus; WAIS=Wechsler Adult Intelligence Scale

Shading indicates summary rows and columns.

None of the eligible studies reported diagnostic outcomes. Five comparative effectiveness trials showed no statistical differences in any cognitive category, despite examining many comparisons.^60, 62, 83, 85, 89^ These trials are likely underpowered for comparative effectiveness.

Baker et al. showed that executive function/attention/processing speed (measured with four different instruments) improved with aerobic exercise compared with stretching in 3 of the 4 tests.^56^ They found no statistically significant difference in memory with aerobic exercise versus stretching.

Taylor-Piliae et al. showed that executive function/attention/processing speed (measured with two different instruments) improved more with Tai Chi than multicomponent physical activity in one of two tests.^95^

Evidence on comparative effectiveness was insufficient due to the heterogeneity in interventions, comparisons, and outcomes examined, resulting in either limited data (n<500 for single studies), or no data.

## Adults With MCI

Conclusions are provided in Table 4B.4 and individual study results in Table 4B.5.

Table 4B.4 Conclusions: Physical activity versus inactive comparisons in adults with MCI

Comparison | Outcome | Conclusion | Strength of Evidence (justification)
Multicomponent physical activity vs. attention control k=1 | Dementia | No data available. | Insufficient (no data)
Multicomponent physical activity vs. attention control k=1 | MCI | No data available. | Insufficient (no data)
Multicomponent physical activity vs. attention control k=1 | Brief cognitive test performance | Unable to draw conclusion. | Insufficient (medium study limitations, indirect, imprecise)
Multicomponent physical activity vs. attention control k=1 | Multidomain neuropsychological performance | Limited data. | Insufficient (limited data)
Multicomponent physical activity vs. attention control k=1 | Memory | Unable to draw conclusion. | Insufficient (medium study limitations, indirect, imprecise)
Aerobic training vs. attention control k=2 | Dementia | Limited data. | Insufficient (limited data)
Aerobic training vs. attention control k=2 | MCI | No data available. | Insufficient (no data)
Aerobic training vs. attention control k=2 | Brief Cognitive Test Performance | No data available. | Insufficient (no data)
Aerobic training vs. attention control k=2 | Multidomain Neuropsychological Performance | Unable to draw conclusion. | Insufficient (medium study limitations, indirect, imprecise, inconsistent)
Aerobic training vs. attention control k=2 | Executive Function | Unable to draw conclusion. | Insufficient (medium study limitations, indirect, imprecise)
Aerobic training vs. attention control k=2 | Memory | Unable to draw conclusion. | Insufficient (medium study limitations, indirect, imprecise)

k=number of studies included; MCI=mild cognitive impairment; vs.=versus

Table 4B.5 Results overview: Physical activity interventions versus inactive comparisons for adults with MCI

Author Year Comparison N= Followup | Diagnosis | Biomarkers [specific biomarker] | Brief Cognitive Test Performance/Multidomain Neuropsychological Test Performance [instrument] | Executive/Attention/Processing Speed [instrument] | Memory [instrument] | Intermediate Outcomes Summary | Adverse Effects [specific adverse effect]
Multicomponent Physical Activity Results Summary k=1; n=100 | NR | 0 of 2 (no difference) k=1 | BCT 1 of 3 favor I k=1 MNP 0 of 1 (no difference) k=1 | 0 of 4 (no difference) k=1 | 1 of 5 favors I k=1 | 2 of 15 favor I | 0 of 1 (no difference) k=1
Suzuki, 2013^93^ Multicomponent physical activity vs. attention control n=100 6 months | | NS [MTA-ERC] | BCT NS [MMSE] | | NS [WMS-LM I] | 0 of 6 (no difference) | NS [Falls and hospitalization for illness]
Suzuki, 2013^93^ Multicomponent physical activity vs. attention control n=100 6 months | | NS [WBC] | MNP NS [ADAS-Cog] | | NS [WMS-LM II] | | NS [Falls and hospitalization for illness]
Suzuki, 2012^94^ Multicomponent physical activity vs. attention control (aMCI subgroup of Suzuki 2013) n=50 6 months 12 months | | | BCT I>C [MMSE, 6 months] | NS [SCWT-I] | I>C [WMS-LM I, 6 months] | 2 of 9 favor I
Suzuki, 2012^94^ Multicomponent physical activity vs. attention control (aMCI subgroup of Suzuki 2013) n=50 6 months 12 months | | | BCT NS [MMSE, 12 months] | NS [SCWT-II] | NS [WMS-LM I, 12 months]
Suzuki, 2012^94^ Multicomponent physical activity vs. attention control (aMCI subgroup of Suzuki 2013) n=50 6 months 12 months | | | | NS [DSST] | NS [WMS-LM II]
Suzuki, 2012^94^ Multicomponent physical activity vs. attention control (aMCI subgroup of Suzuki 2013) n=50 6 months 12 months | | | | NS [LVFT]
Aerobic Training Results Summary k=2; n=153 | 0 of 1 (no difference) k=1 | NR | MNP 1 of 2 favors I k=2 | 0 of 8 (no difference) k=2 | 0 of 5 (no difference) k=2 | 1 of 16 favor I | 0 of 4 (no difference) k=2
Hildreth, 2015^67^ Endurance training vs. usual care + placebo (for control for pioglitazone arm) n=53 6 months | | | MNP NS [ADAS-Cog] | NS [WMS-R VR II] | NS^a^ [Memory Composite] | 0 of 11 (no difference) | Unclear [Musculo-skeletal Complaints]
Hildreth, 2015^67^ Endurance training vs. usual care + placebo (for control for pioglitazone arm) n=53 6 months | | | | NS [Picture Completion, WAIS-R] | NS [WMS-R, LM II]
Hildreth, 2015^67^ Endurance training vs. usual care + placebo (for control for pioglitazone arm) n=53 6 months | | | | NS^b^ [Executive Function Composite] | NS [RAVLT]
Hildreth, 2015^67^ Endurance training vs. usual care + placebo (for control for pioglitazone arm) n=53 6 months | | | | NS [TMT B]
Hildreth, 2015^67^ Endurance training vs. usual care + placebo (for control for pioglitazone arm) n=53 6 months | | | | NS [DSST]
Hildreth, 2015^67^ Endurance training vs. usual care + placebo (for control for pioglitazone arm) n=53 6 months | | | | NS [SCWT]
Hildreth, 2015^67^ Endurance training vs. usual care + placebo (for control for pioglitazone arm) n=53 6 months | | | | NS [DSST]
Lautenschlager, 2008^74^ Home-based physical activity vs. information control n=100 6 months | NS [CDR, Sum of Boxes (diagnosis estimate)] | | MNP I>C [ADAS-Cog] | NS [DSST] | NS [Word List, Immediate Recall] | 1 of 5 favor I | NS [Cardiovascular Problem] NS [Stroke] NS [Shoulder Operation]
Lautenschlager, 2008^74^ Home-based physical activity vs. information control n=100 6 months | | | | | NS [Word List, Delayed Recall] | | NS [Cardiovascular Problem] NS [Stroke] NS [Shoulder Operation]

a Scaled score for domain: visual reproduction II, logical memory II, RAVLT;

b Domain scaled score: TMT B, DSST

Shading indicates summary rows and columns.

ADAS-Cog=Alzheimer’s Disease Assessment Scale-Cognitive Subscale; BCT=brief cognitive test performance; C=inactive control; CDR=Clinical Dementia Rating; DSST=Digit Symbol Substitution Test; I=intervention; k=number of studies included; LM=logical memory; LVFT= letter verbal fluency test; MCI=mild cognitive impairment; MMSE=Mini-Mental State Examination; MNP=multidomain neuropsychological test performance; MTA-ERC=medial temporal areas including the entorhinal cortex; n=sample size; NS=no statistically significant difference; RAVLT=Rey Auditory Verbal Learning Test; SCWT=Stroop Color and Word Test; TMT=Trail-Making Test (A and/or B); VR=Visual Reproduction; vs.=versus; WAIS-R=Wechsler Adult Intelligence Scale-Revised; WMS=Wechsler Memory Scale; WBC= whole brain cortices

### Efficacy: Physical Activity Versus Inactive Control

We identified four reports of three unique studies comparing physical activity interventions to inactive controls in older adults with MCI.^67, 74, 93, 94^ Lautenschlager et al. (n=170) compared a 24-week home-based exercise program with usual care.^74^ Hildreth et al. (n=78) compared a 6-month endurance exercise program with placebo in obese older adults with MCI.^67^ Suzuki et al. compared a 6-month multicomponent physical activity program to attention control in older adults with MCI or amnestic MCI.^93^

All three trials reported multidomain neuropsychological test performance measured with the Alzheimer’s Disease Assessment Scale-Cognitive Subscale (ADAS-Cog). Lautenschlager et al. showed improvements with the home-based physical activity program versus usual care.^74^ Hildreth et al. showed no statistical difference with endurance exercise versus placebo (for control for a pioglitazone arm) and no exercise.^67^ Suzuki et al. showed no statistical difference with a 6-month multicomponent physical activity program versus attention control.^93^ Lautenschlager et al. showed no difference in executive function/attention/processing speed with home exercise versus usual care compared using two different measures.^74^ Hildreth et al. used four tests to measure executive function/attention/processing speed and found no differences in any measure.^56^ Suzuki et al. showed no difference in memory with multicomponent exercise versus attention control measured with two different measures.^93^

We identified six reports of five unique studies comparing physical activity interventions to active interventions in older adults with MCI.^56, 72, 73, 75, 81^ All were assessed high risk of bias.

## Interpreting the Findings

These results show no clear and consistent benefit of physical activity interventions in preventing cognitive decline. However, the number of positive results exceeds what would be expected by chance alone; providing a signal of a possible relationship. Given that many of these physical activity intervention studies enrolled older sedentary adults and had followup times as short as 6 months, substantial benefits to cognition might be unlikely. If physical activity lowers risk for cognitive decline and CATD and interventions can be effectively implemented to change behaviors, these interventions likely involve long-term investment and may need to begin earlier in the aging process. Long-term studies enrolling younger adults would greatly benefit the field and provide important insight on prevention.

* Note that the literature currently does not use the term CATD; we specified whenever the diagnosis of dementia was defined.