# 4A Results: Cognitive Training

## Key Messages

- Most studies addressed intermediate outcomes of cognitive training in terms of cognitive performance and a few measures of brain activity.
- The Advanced Cognitive Training for Independent and Vital Elderly (ACTIVE) trial provided the strongest and most comprehensive design to assess the effect of cognitive training on cognitive performance for older adults with normal cognition. Its results provide moderate-strength evidence at 2 years (but low-strength at 5 and 10 years) that cognitive training can improve cognitive function in the domain trained, but transfer to other domains was rare. There is some suggestion that processing speed training is associated with improved instrumental activities of daily living (IADL) performance, but longer term studies were rated as low strength of evidence.
- Other than the ACTIVE trial, the few studies that examined clinical Alzheimer’s-type dementia (CATD)^*^ incidence or cognitive performance showed mixed results.

## Eligible Studies

Out of the 38 studies of cognitive training interventions that met inclusion criteria after review of full text, only 11 studies (12 articles) had medium or low risk of bias. Appendix F provides evidence tables, summary risk of bias assessments, and assessments of strength of evidence for key comparisons and outcomes.

We assessed strength of evidence based on a best-evidence approach, using the trial best designed to test the question of interest. Other relevant trials are then presented in followup sections as context for and consistency with best evidence.

## Advanced Cognitive Training for Independent and Vital Elderly (ACTIVE) Trial

The ACTIVE trial is the most ambitious study to date to test alternative forms of cognitive training. It has received wide attention and serves as a model for subsequent work. The overarching goal of the study was to test whether different types of cognitive training could improve daily life (as captured in IADLs, problem solving, and speed of performance); but also improved cognitive performance, which as an intermediate outcome is a focus of interest for this review. Its findings have been interpreted differently by various groups of investigators.^16, 23, 24^

Among the large number of publications from the ACTIVE trial, we actively discuss four, three of which reported the results for proximal and primary outcomes, as described in the ACTIVE protocol, at 2 years,^25^ 5 years,^26^ and 10 years.^27^ We include the latter two publications although they have high risk of bias because of the salience of the topic. The fourth study looked at incident dementia at 5 years.^28^ Although assessing dementia was not part of the original ACTIVE protocol and was rated as having high risk of bias, we include the latter study because this outcome is of particular interest for our review. Conclusions based on the ACTIVE trial are provided in Table 4A.1.

Table 4A.1 Conclusions: Cognitive training in adults with normal cognition

Comparison | Outcome | Conclusion and Effect Size (ES) | Strength of Evidence (justification)
Cognitive training k=1 | Dementia | Unable to draw conclusion. | Insufficient (high study limitations, imprecise)
Cognitive training k=1
Cognitive training k=1 | MCI | Unable to draw conclusion. | Insufficient (high study limitations, imprecise)
Cognitive training k=1
Cognitive training k=1 | Reasoning | Improvement with reasoning training (ES=0.26). No significant differences with memory or speed of processing training. (n=2,832; 2 years). | Moderate (medium study limitations, indirect)
Cognitive training k=1 | Reasoning | Improvement remained at 5 (ES=0.26) and 10 years (ES=0.23) | Low (high study limitation, indirect, precise)
Cognitive training k=1
Cognitive training k=1 | Processing speed | Improvement with speed of processing training (ES=0.87). No significant differences with reasoning or memory training. (n=2,832; 2 years). | Moderate (medium study limitations, indirect)
Cognitive training k=1 | Processing speed | Improvement remained at 5 (ES=0.76) and 10 years (ES=0.66). | Low (high study limitation, indirect, precise)
Cognitive training k=1
Cognitive training k=1 | Memory | Improvement with memory training intervention (ES=0.17). No significant differences with reasoning speed of processing training. (n=2,832; 2 years). | Moderate (medium study limitations, indirect)
Cognitive training k=1 | Memory | Improvement remained at 5 (ES=0.23) but not 10 years. | Low (high study limitation, indirect)

ES=effect size; k=number of studies included; MCI=mild cognitive impairment; n=sample size

Between March 1998 and October 1999, 2,832 adults aged 65 years or older whose Mini-Mental State Examination (MMSE) scores were ≥23, and who were living independent of formal care were enrolled in the trial at one of the five ACTIVE field centers. Participants were randomized to one of three training arms or a no-contact control arm. Each of the training arms targeted a different domain: memory, reasoning, or processing speed. Proximal outcomes (changes on cognitive testing), primary outcomes (changes in functioning, everyday problem solving, driving), and secondary outcomes (health service utilization, mobility, quality of life) were evaluated. Because each arm focused on a different domain, we can contrast the specific effects of training on the extent of spillover, or transfer, into other domains as well as to explore the impact of each arm on more generalizable effects like IADLs. (The ACTIVE trial included other outcomes, such as depression and specific performance of tasks like driving, which were not judged salient to the Key Questions in this review.)

The three intervention arms: 1) provided strategies for solving problems, remembering, or responding quickly to information; 2) used trainers to demonstrate the strategy; 3) incorporated individual and group exercises; 4) provided feedback on performance; 5) fostered self-efficacy with regard to performance; and 6) applied strategies to real-world tasks. In all three conditions, the first five sessions focused on strategy instruction and exercises to practice the strategy, while the last five sessions provided additional practice exercises but introduced no new strategies. Content for each of the 10 sessions was scripted in a trainer’s manual. The first set of sessions emphasized cognitive performance, whereas the last five sessions emphasized adaptation to daily life. Initial training was conducted between May 1998 and December 1999. The reasoning and speed of processing arms, but not the memory arm, were tailored to participant baseline performance.^29^ Booster training at 1 and 3 years (1 month before testing) was given to a random sample of participants in each arm who completed the initial ten sessions.

Memory was evaluated using the Hopkins Verbal Learning Test, Rey Auditory-Verbal Learning Test, and the Rivermead Behavioral Memory Test. Reasoning was evaluated using the word series, letter series, and letter sets tests. Speed was evaluated using Digit Symbols Substitution, Digit Symbols Copy, and the Useful Field of View (UFOV) test. All measures were traditional examiner-administered tests with the exception of the computer-based UFOV. Timed IADL was assessed for five tasks: using a phone book, reading food and medication labels, finding an item on a crowded pantry shelf, and counting change.

Findings from the four studies are summarized in Table 4A.2. Only the 2-year outcome study had a medium risk of bias.^25^ As noted above, the 5-year and 10-year outcome studies had a high risk of bias due to attrition but are retained here because of the scarcity of long-term followup studies. Attrition at 5 years was 33 percent based on enrollment numbers (attrition rates were essentially the same for all arms including controls); attrition at 10 years was 57 percent (55 percent attrition for reasoning and speed arms, 58 percent for memory arm, and 60 percent for control arm), but only about 18 percent of the sample loss at 5 years was attributable to death. Thus, much of the sample loss was unexplained. By 10 years, death accounted for about 25 percent of the attrition. Participant factors that predicted 10-year attrition included: being older, male, or unmarried; having physical or mental health concerns; consuming more alcohol; and exhibiting worse performance on cognitive outcomes. Predictors of attrition were reported as similar across arms. Efforts were made to assess the impact of attrition, including using linear mixed methods, multiple imputation, survival analysis, and sensitivity analysis, but none of these efforts completely excluded attrition effects. Further, the studies did not indicate whether those who withdrew by virtue of self-reported or proxy-reported dementia were assigned to the worse cognitive category. Finally, the booster effect was also biased, because those receiving boosters had a compliance rate on the initial training of 80 percent or better. We rated the strength of evidence for the 2-year outcomes as moderate, but for the reasons discussed above, the 5- and 10-year outcomes were rated low.

Table 4A.2 Key ACTIVE studies

Characteristics | Ball, 2002^25^ | Willis, 2006^26^ | Unverzagt, 2012^28^ | Rebok, 2014^27^
Risk of Bias | Medium | High | High | High
N completed / randomized | 2,244/2,832 | 1,879/2,832 | 1,879/2,832 | 1,220/2,832
Attrition (%) | 21% | 33% | 33% | 57%
Followup Duration | 2 years | 5 years | 5 years | 10 years
Design | For all three arms, the intervention was administered in a small-group setting (3–4 preferred, 5 maximum) by a certified trainer. Participants received 10, 60- to 70-minute trainings over 6 weeks. Sixty percent of the compliant initial sample (those attending at least 8 of the 10 sessions) were randomly chosen to receive two booster training interventions at about 1 year and 3 years. Each booster included four sessions that were similar in content and structure to the initial training.
Testing Outcomes | Cognitive Testing in Domains Related to Training (Memory, Reasoning, Speed) | None | Cognitive Testing in Domains Related to Training (Memory, Reasoning, Speed) | Cognitive Testing in Domains Related to Training (Memory, Reasoning, Speed)
Primary Outcomes | Everyday Problem Solving, Everyday Speed, IADL/ADL, Driving Habits | Dementia Diagnosis (estimated) | Everyday Problem Solving, Everyday Speed, IADL/ADL, | Everyday Problem Solving, Everyday Speed, IADL/ADL,
Key Findings | - Participants improved on tests related to the domain in which they were trained and not the other domains; - Broader outcomes (e.g. everyday problem-solving, functioning, and driving) were not affected by trainings | - Participants improved on tests related to the domain in which they were trained and not the other domains; - Reasoning training (not memory or speed) improved IADLs at 5 years | - Hazard model (based on original sample of 2,832) to assess risk of incident dementia over five year period; - Cases of incident dementia did not differ between intervention (combined) and control arms; - Incidence of dementia was higher for people with diabetes, heart failure and stroke/TIA | - Participants in speed and reasoning arms sustained improvement on tests related to the domain in which they were tested but not the other domains; - Memory improvement was no longer sustained for participants in memory arm; - Participants in each intervention group reported less difficulty with self-reported instrumental activities of daily living

ADL=activities of daily living; IADL=instrumental activities of daily living; TIA=transient ischemic attack

The ACTIVE trial was not designed to study the incidence of dementia, and no psychometrically or clinically valid measures of dementia were included. Regular contact with the cohorts was not maintained, and reasons for sample loss were not well established. In the Unverzagt study the determination of dementia relied on three different sources (MMSE, a decrease in the cognitive composite measure of 1.5 standard deviations (SD), or a report from a proxy or the subject that the subject had dementia).^28^ For the purpose of this analysis, dementia was defined as the first occasion of measurement (immediate post-test, 1-year, 2-year, 3-year, and 5-year followup) in which a participant had any of these outcomes: 1) Memory composite 1.5 SD below the ACTIVE sample baseline mean; and Reasoning composite, Speed composite, or Vocabulary 1.5 SD below the mean; and functional impairment defined as MDS IADL Total Performance at or below the 10th percentile of the ACTIVE sample baseline; 2) first visit in which MMSE<22 and all subsequent visits are MMSE<22 or are missing; 3) interval self- or proxy-report of diagnosis of dementia or Alzheimer disease during the followup; 4) interval self- or proxy-report of institutionalization during the followup; or 5) deactivation from the study due to the family refusing access to the subject. Because some participants who were lost to followup were inferred to have dementia, the purported dementia rates are confounded by the attrition rates. A sensitivity analysis that assigned all those assumed to have dementia and who were not retested to a low performance level on cognitive tests could provide one estimate of long-term effects, although the dementia may not have affected all areas of performance equally. Baseline impairment was associated with a higher rate of dementia as classified by the study. So, too, was the drop-out rate. We rated the strength of evidence for this aspect of the ACTIVE portfolio as insufficient.

Overall, as shown in Table 4A.3, at 2 and 5 years participants did better in the domain for which they received training and not the other domains (except speed positively affects reasoning at 5 years). These advantages are sustained for up to 10 years for two of the three domains (reasoning and speed of processing training). The effect sizes for memory and reasoning are modest. The effect size for speed of processing training is medium to large. (Bear in mind that high attrition in all arms could create bias.)

Table 4A.3 Effect of domain specific training on 2-, 5-, and 10-year cognitive testing outcomes (reported as effect sizes)

Timing | Outcomes | Memory | Reasoning | Speed of Processing
2-year Outcomes | Memory | 0.17 ^ * ^ | 0.03 | 0.05
2-year Outcomes | Reasoning | 0.05 | 0.26 ^ * ^ | 0.02
2-year Outcomes | Speed of Processing | −0.03 | −0.04 | 0.87 ^ * ^
5-year Outcomes | Memory | 0.23 ^ * ^ | 0.05 | 0.05
5-year Outcomes | Reasoning | 0.01 | 0.26 ^ * ^ | 0.02
5-year Outcomes | Speed of Processing | 0.01 | 0.15 ^ * ^ | 0.76 ^ * ^
10-year Outcomes | Memory | 0.06 | 0.11 | 0.05
10-year Outcomes | Reasoning | 0.02 | 0.23 ^ * ^ | 0.06
10-year Outcomes | Speed of Processing | 0.07 | 0.01 | 0.66 ^ * ^

* p<.01 (also noted by bold font)

Effect size = (group mean-control mean at time point) − (group mean at baseline) divided by intrasubject standard deviation

Table 4A.4 shows the mean change in test score by treatment arm. These should be interpreted in the context of the score range of the domain scores. Statistically significant improvements in the memory and reasoning arms are not associated with large changes in actual mean scores. For example, at 5 years the memory-training group showed a mean change of one point on a 132-point scale. By contrast, speed of processing showed a gain of 240 points out of a possible 1500. By 10 years, that gain, while still significant, had fallen to 24 points. The other arms, by contrast, showed actual losses in performance. All of these findings must be viewed while recognizing the attrition rates.

Table 4A.4 Effect of domain specific training on 5- and 10- year cognitive testing outcomes (mean changes in test score from baseline)

Timing | Outcome | Memory | Reasoning | Speed of Processing | Control
5-year Outcomes | Memory (possible range 0–132) | −1.0^*^ | −4.8 | −5.3 | −4.0
5-year Outcomes | Reasoning (possible range 0–75) | 4.3 | 8.1 ^ * ^ | 4.2 | 5.2
5-year Outcomes | Speed of Processing (possible range 0–1500) | 79.1 | 119.6 ^ * ^ | 241.8 ^ * ^ | −96.1
10-year Outcomes | Memory (possible range 0–132) | −10.6 | −11.2 | −12.7 | −9.4
10-year Outcomes | Reasoning (possible range (0–75) | −3.5 | −0.1^*^ | −3.9 | −3.0
10-year Outcomes | Speed of Processing (possible range 0–1500) | −144.4 | −126.2 | 24.3 ^ * ^ | −123.3

* p<.01 (also noted by bold font)

Effect size = (group mean-control mean at time point) − (group mean at baseline) divided by intrasubject standard deviation

As shown in Tables 4A.5, compared to participants who did not receive reasoning training, participants who received reasoning training and were assessed at five years showed significant benefits in IADLs, but no changes in incident dementia were observed at 5 years. By the 10-year assessment all participants showed significant benefits in IADLs. Reasoning and speed training were associated with fewer motor vehicle collisions.^30, 31^ Depression was assessed but was deemed outside of this review’s scope.^32, 33^ Again, the high attrition rates need to be considered.

Table 4A.5 Effect sizes for various activity outcomes

Timing | IADL Outcome | Memory | Reasoning | Speed of Processing
2-year Outcomes | Every day problem solving | 0.07 | 9.03 | 0.03
2-year Outcomes | ADL/IADL | 0.02 | 0.06 | 0.07
2-year Outcomes | Everyday speed | 0.01 | 0.03 | 0.01
2-year Outcomes | Driving Habits | 0.09 | 0.03 | 0.08
5-year Outcomes | Every day problem solving | 0.15 | 0.08 | 0.05
5-year Outcomes | ADL/IADL | 0.20 | 0.29 ^ * ^ | 0.26
5-year Outcomes | Everyday speed | 0.04 | 0.09 | 0.08
5-year Outcomes | Driving Habits | NR | NR | NR
10-year Outcomes | Every day problem solving | 0.00 | 0.02 | 0.01
10-year Outcomes | ADL/IADL | 0.48 ^ * ^ | 0.38 ^ * ^ | 0.36 ^ * ^
10-year Outcomes | Everyday speed | 0.02 | 0.00 | 0.05
10-year Outcomes | Driving Habits | NR | NR | NR

* p<.01 (also noted by bold font)

Effect sizes = (group mean-control-mean at time point) − (group mean − control mean at baseline) divided by intrasubject standard deviation. ADL=activities of daily living; IADL=instrumental activities of daily living; NR=not reported

In an effort to establish generalizability, Prindle and McArdle^34^ compared the demographic characteristics of the ACTIVE sample to the sample in the Health and Retirement Study,^35^ a representative sample of about 20,000 Americans. They found similar patterns of measurable demographic variables, but cannot correct for unmeasured differences in cognition or other factors associated with volunteering for the study. Likewise, additional analyses focused on participants with algorithmic classification of cognitive impairment and found no difference between participants with low cognition versus those who were not low.^36, 37^

In a study with only a 6-week followup Edwards and her colleagues showed an improvement in timed IADLs after speed of processing training.^38^ A second 6-week study, where outcomes were assessed upon completion of training, addressing only those with initial deficits also showed short-term improvement in timed IADL performance.^39^

## Other Studies

We were unable to standardize scores for the cognitive tests. Reliable change indices (RCIs) for most of the tests were not available. We were uncertain about the applicability of the RCIs, as they may not account for differences across populations.^40^ It was unclear whether a RCI calculated from a population with normal cognition accurately would capture clinically meaningful change in a population with mild cognitive impairment. In addition, several of the included studies were conducted in international settings. Previous research shows that a RCI may differ across racial and ethnic groups.^41^

We were able to calculate effect size (Cohen’s D) for five studies. Three studies had participants with normal cognition (Miller 2013,^42^ Klusmann 2010,^43^ and Carretti 2012^44^) and two studies had participants with mild cognitive impairment (MCI) (Rapp 2002,^45^ Herrera 2012^46^). We were also able to extract effect sizes and 95% confidence intervals reported in Wolinksy, et al. 2013, which had participants with normal cognition.^47^ Four studies reported insufficient data to calculate effect size (Buschert 2012^48^ & Forster 2011,^49^ Kwok 2012,^50^ Vidovich 2015,^51^ Stine-Morrow 2014^52^).

### Effect of Training on Adults With Normal Cognition

Five of the included trials tested the effect of cognitive training interventions on older adults with normal cognition.^42–44, 47, 52^ Three of the five trials for older adults with presumed normal cognition used computer-based interventions;^42, 43, 47^ two of which used computer programs directly targeting specific cognitive domains and administered the training individually;^42, 47^ one trial used a more general- or activity- based approach to cognitive training by teaching participants how to perform basic tasks on a personal computer in groups of 12 participants.^43^ Two trials used a noncomputer-based intervention.^44, 52^

Table 4A.6 describes the included trials that tested the effects of cognitive interventions for older adults with normal cognition.

Table 4A.6 Training interventions for older adults with normal cognition

Author, Year Risk of Bias | N Completed/Randomized Attrition (%) Followup | Domains Trained | Mode | Intensity | Testing Outcomes | Patient-Centered Outcomes; Other Outcomes | Key Findings
Wolinsky, 2013^47^ Low | 620/681 9% 1 year | Speed of processing | Individual, computer-based training | 10 hours over 5 weeks, booster at 11 months | Primary outcome = Useful Field of View (UFOV) test | None | - Used one of the ACTIVE tools, speed of processing arm; - Found significant changes on domain trained using UFOV test; - Mixed results on 9 other secondary testing outcomes
Miller, 2013^42^ Medium | 69/84 18% 6 months | Short- & long-term memory, language, visual/spatial processing, reasoning, calculation | Individual, computer-based training | 13 hours over 8 weeks | Delayed memory, immediate memory, & language | None | - Computer program trained 5 domains; - Only 2 of the 5 domains (or 3 of 6 depending on how you count long vs. short term memory) were formally tested; - Only delayed memory showed improvement (immediate memory and language not significant); - Individual tests combined in results to present a “domain score”
Klusmann, 2010^43^ Medium | 230/259 11% 6 months | None specifically trained | Group, computer-based training | 112.5 hours over 6 months of in-class instruction (90 minutes per session) | Delayed memory, immediate memory, & executive attention | None | - Computer training resulted in statistically significant improvements in story recall (immediate and delayed), free recall (long delay), and one of the two tests of executive functioning/attention (TMT B/A).; - Computer training did not improve free recall (short delay), verbal fluency, or executive functioning (as measured with the Stroop test); - Effect sizes for statistically significant improvements were small
Carretti, 2013^44^ Medium | 36/40 4% 6 months | Working memory | Individual, computer-based training | 2.5–3.5 hours over 2 weeks (50–70 minutes per session, 3 sessions total) | Working memory, listening comprehension, reading comprehension, and fluid intelligence. | None | - Participants who received working memory training showed improvements in working memory, and listening comprehension compared with controls.; - Working memory training did not improve reading comprehension or fluid intelligence compared with control.
Stine-Morrow, 2014^52^ Medium | 395/461 14% 8 months | Reasoning (cognitive training arm), divergent thinking (engagement arm) | Group, non-computer based or individual, non-computer based | 24 hours over 16 weeks of formal engagement, with 15 hours per week of work related to team-based project in engagement arm | Processing speed, verbal episodic memory, visual/spatial processing, reasoning and divergent thinking | None | - Participants did better in domain for which they were trained (reasoning for training arm, divergent thinking for engagement arm); - Spillover effects were not observed, engagement or training did not improve processing speed, visual-spatial, or verbal episodic memory compared with waitlist controls.

ACTIVE=Advanced Cognitive Training for Independent and Vital Elderly; TMT B/A=Trail Making Test B and A; UFOV=Useful Field of View

The Iowa Health and Active Minds Study (IHAMS) used a version of the speed of processing tool from the ACTIVE trial.^47^ Six hundred eighty-one adults with normal cognition were randomized separately based on their age at baseline (50–64 year-olds vs. 65 or older). Similar to the ACTIVE design, a booster was provided, but here to a pre-randomized group at 11 months. (Unlike ACTIVE, the booster assignment was made at the outset.) The authors used a university-based attention control activity (computerized crosswords) compared with one of three active intervention arms (visual speed of processing training at the university, visual speed of processing training at the university with a booster, or the same visual speed of processing training at home on the participant’s personal computer). Ten hours of training were provided over 5 weeks (similar to ACTIVE). Outcomes were assessed at baseline and at 6 months and 1 year post-training. The primary outcome was determined using the UFOV test. Similar to the ACTIVE trial, the IHAMS found the visual speed of processing intervention positively affected tests of performance in that domain up to 1 year post-intervention (effect size 0.32 onsite, 0.37 at home, and 0.58 with booster, favoring the intervention). Nine additional cognitive tests were administered: Trail Making Tests (TMT) A and B, Symbol Digit Modalities Test (SDMT), Stroop Color and Word Tests (3 tests), Controlled Oral Word Association Test (COWAT), and the Digit Vigilance Test (DVT). Many of these additional tests can evaluate higher-order cognitive domains (e.g., executive functioning) than the training specifically targeted. For the onsite training interventions, significant effects of training on these secondary outcomes were found on TMT A, SDMT, and Stroop-Word, but not TMT B, Stroop-Color, Stroop Color-Word, COWAT, or DVT. For the onsite training intervention with boosters, significant effects of training on these secondary outcomes were found on TMT B, SDMT, and Stroop-Word, but not TMT A, Stroop-Color, Stroop Color-Word, COWAT, or DVT. For the at home training, significant effects of training on these secondary outcomes were found on TMT A and B, SDMT, and Stroop-Word, but not Stroop-Color, Stroop Color-Word, COWAT, or DVT. Across all of the secondary outcomes, effects sizes were smaller than in the trained domain and few exceed 0.5. This may suggest more potential for cognitive transfer than that seen in the ACTIVE study, although one cannot rule out that the timed nature of the tests may be driving improvement. Also, the large number of analyses needs to be kept in mind. Of the 30 analyses that were done, six had a positive Cohen’s D. Effect sizes were generally small; few exceeded 0.5. The UFOV results were meant to reflect skills useful in daily life (e.g., driving) but were not necessarily evidence of overall cognitive performance.

The study by Miller was much smaller, enrolling just 84 participants.^42^ The intervention was an individual-level, computerized, brain-training program focusing on six domains (short- and long-term memory, language, visual spatial processing, reasoning, and calculation). Presumably cognitively normal participants were asked to use the program 20–25 minutes a day, 5 days a week, for 8 weeks. Outcomes were evaluated by domain-specific tests of immediate memory, delayed memory, and language (visual spatial processing, reasoning, and calculation not evaluated). Outcomes were evaluated at baseline and at 2 months and 6 months. Individual tests were combined and only overall domain scores were reported. Only one of the three domains showed significant improvement (delayed memory). Measures of overall cognition were not reported. None of the six memory tests reported in the study had a positive Cohen’s D in our analysis.

The Klusmann trial was conducted in Berlin, Germany, and enrolled 259 nondepressed women with over the age of 70.^43^ Participants were randomized to a computer-based cognitive intervention, a physical activity intervention, or a nonintervention control arm. The cognitive intervention was a group computer courses taught approximately three times per week, 90 minutes per class, for 6 months. Course activities included: learning to email and use the internet, taking and editing pictures or videos, playing games, word processing, or drawing. Neuropsychological testing was conducted using traditional examiner administered tests at baseline and at 6 months post-intervention. Tests measured: immediate and delayed story recall (RBMT), short and long delay free word recall (FCSRT), semantic verbal fluency, and executive functioning tasks (Stroop, TMT B/A). Six months of computer classes significantly improved immediate and delayed story recall, free recall (long delay), and one of the two tests of executive functioning (TMT B/A), compared with a no intervention control. Computer training did not improve free recall (short delay), verbal fluency, or the other executive measure (Stroop). This Cognitive Training Chapter of our report is restricted to comparisons between the cognitive intervention arm and the no-contact control. However, it is notable that the exercise and cognitive interventions resulted in significant changes on the same tests at followup, compared with no-contact controls. Of the four memory tests included in the study, two (RBMT immediate and delayed recall) showed positive Cohen’s D. The effect sizes for both were 0.33. Neither of the two tests of executive/attention/processing speed domains showed positive Cohen’s D. Klusmann et al. argue that this outcome may be due to improved “management of new complex situations,” and not training mental “muscles,” as may be supposed for domain-specific training.

The study by Carretti et al. was a small trial, enrolling just 40 participants.^44^ The intervention was individual-level working memory training using audio recordings for word recall and computers for text recall. Participants in the intervention group were asked to complete three training sessions, 50–70 minutes each, over a 2-week period with 2 days between sessions. The control group also attended three sessions with experimenters where they filled out paper-pencil questionnaires. Outcomes were evaluated at baseline, after completing training, and at 6 months. Outcomes measures included tests of working memory, listening comprehension, reading comprehension, and fluid intelligence. Participants receiving working memory training showed significant improvements in working memory and listening comprehension outcomes compared with those in the control group. No significant differences were observed between groups for reading comprehension or fluid intelligence outcomes. The Cohen’s D values for the memory tests were quite high, ranging between 1.4 to 1.9.

Another pathway through which group activities may affect cognitive outcomes is through social engagement. The Stine-Morrow et al. study aimed to test the differential effects of domain-specific cognitive training and engagement activities that may broadly stimulate the mind.^52^ This study enrolled 461 adults with normal cognition over the age of 60 who were doing less than 15 hours of scheduled activity (work or volunteering) per week. Subjects were randomized to a group intervention aimed at engagement and problem-solving, an individual intervention with cognitive training in inductive reasoning, or a waitlist control. In the engagement arm, participants were put in teams, practiced weekly, and competed in the Odyssey of the Mind—a tournament-style competition in which teams are judged on their ability to develop a solution to a novel problem without preparation and on their ability to present a solution to a problem that they have prepared in advance. The training arm consisted of paper-pencil weekly lessons and activities focused on inductive reasoning. Both active intervention arms were 16 weeks (including breaks for winter holidays and weather-related cancelations). Posttests were conducted between 30 and 32 weeks. Five cognitive domains were assessed before and after the intervention: processing speed (Letter and Pattern Comparison, Finding As), reasoning (Letter Sets, Number Series, Letter Series, Word Series, everyday problem-solving), visual-spatial processing (card rotation, hidden patterns), divergent thinking (alternate uses task, opposites task), verbal episodic memory (Hopkins Verbal Learning Test, delayed recall score, and immediate sentence free-recall). Participants in the training arm showed greater improvement in reasoning (the skill to which they were trained) than the engagement or control arms. Improvements in reasoning between the engagement and control arms did not differ. Participants in the engagement arm showed greater improvements in the divergent thinking outcome (also the skill they practiced) than the training and waitlist arms. However, generalizations of training to other cognitive abilities from either intervention arm were not observed. No significant differences were seen in processing speed, visual-spatial, or verbal episodic memory between study arms.

### Effect of Training on People With Mild Cognitive Impairment

Five included studies (six articles) enrolled participants with MCI or memory complaints (Table 4A.7). The studies used group interventions that were not computer-based.

Table 4A.7 Cognitive testing interventions for adults with mild cognitive impairment

Author, Year Risk of Bias | N Completed/Randomized Attrition (%) Followup | Domains Trained | Mode | Intensity | Testing Outcomes | Patient-Centered Outcomes; Other outcomes | Key Findings
Buschert, 2012^53^ Forster, 2011^49^ Medium | 18/24 21% 28 months | Mnemonic memory training | Small group (12 participants) | 12 hours over 6 weeks | Brief cognitive test performance/Multidomain neuropsychological test performance (ADAS-Cog, MMSE), Immediate & delayed memory (RBANS), TMT A & B | Conversion to CATD; Glucose uptake (PET scans) | - Intervention improved 1 of 2 global cognitive measures (ADAS-cog); - 1 of 4 domain-specific tests was significantly improved (RBANs immediate memory);; - Forster study reports FDG-PET results: intervention group showed no decline in uptake during the 6-months, while control showed widespread decline in uptake.; - Half of the control/delayed intervention group converted to CATD during the 28 month followup, but none of the early intervention group converted to CATD
Rapp, 2002^45^ Medium | 16/19 16% 6 months | Memory | Small group (Size not reported) | 12 hours over 6 weeks | Word list (immediate and delayed). shopping list (immediate and delayed), names and faces (immediate and delayed), paragraph (immediate and delayed) | Self-rated memory (Memory Functioning Questionnaire) | - No significant effects of training at 6 months on the eight objective measures of memory; - Present memory self-rated higher in intervention group at 6 months
Vidovich, 2015^51^ Low (1 year outcome only) | 154/160 38% 24 months (reported 12 months) | Attention, memory, executive processes | Small group (6–9 participants) | 15 hours over 5 weeks | Brief cognitive test performance/Multidomain neuropsychological test performance (CERAD, MMSE, CAMCOG-R), Memory (CVLT-II), Attention or Processing (DS Forward, Symbol Search, TMT A), executive (COWAT, TMT B) | Perception of memory (Memory Functioning Questionnaire) | - 1 of 9 cognitive assessments (DS Forward) showed slightly significant effects of intervention at 1 and 2 years; - No differences in brief cognitive test performance/multidomain neuropsychological test performance measures or perceptions of memory were found
Kwok, 2012^50^ Medium | 197/223 12% 12 months | Attention/processing speed, memory, reasoning | Small-group (3–5 participants) | 18 hours over 12 weeks | Brief cognitive test performance/Multidomain neuropsychological test performance (Chinese MMSE, Chinese Mattis Dementia Rating Scale) | Subjective memory complaints | - Intentionally uses same domains as ACTIVE, but different tools used to assess; - Although they were using global measures of cognition, only domain scores reported in results section (unclear from which tools domains originated); - Training did not affect domain scores overall, but did improve scores for those subgroup with less education
Herrera, 2012^46^ Medium | 22/22 No attrition reported 6 months | Recognition, working memory, recall | Individual, computer-based | 24 hours over 12 weeks | Recognition (Doors Recognition Sets A and B, DMS48), Working memory (DS Forward and Backward), Recall (BEM-144 12-word-list, 16-Item free and cued, MMSE 3 words, Rey Complex Figure) | None | - Results were mixed; - 1 of 3 recognition tests improved at 6 months; - 1 of 2 working memory tests improved at 6 months; - 2 of 4 recall tests improved at 6 months

ACTIVE= Advanced Cognitive Training for Independent and Vital Elderly; ADAS-Cog=Alzheimer’s Disease Assessment Scale-Cognitive Subscale; BEM-144= Batterie d’Efficience Mnesique 144; CATD=clinical Alzheimer’s-type dementia; CERAD= Consortium to Establish a Registry for Alzheimer’s Disease; CAMCOG-R=Cambridge Cognitive Examination-Revised; COWAT=Controlled Oral Word Association Test; CVLT-II=California Verbal Learning Test-Second Edition; DS=Digit Span (Forward & Backward); DMS48=delayed matching-to-sample task; FDG-PET=fluorodeoxyglucose positron emission tomography; MMSE=Mini Mental State Examination; PET=positron emission tomography; RBANS=Repeatable Battery for Neuropsychological Status; TMT A/B=Trail Making Test A & B

In one trial, 24 participants were randomized to receive either 12 hours of cognitive training, including formal mnemonic memory training and informal activities to foster cognitive and social engagement, or a control condition that involved monthly paper-pencil activities.^48, 49^ A crossover design was used. The intensity and duration of the intervention was similar to the ACTIVE and IHAMS trials: 2 hours a week for 6 weeks. The target in this study was brief cognitive test performance/multidomain neuropsychological test performance as measured by the Alzheimer’s Disease Assessment Scale-Cognitive subscale (ADAS-Cog) and MMSE. However, three other domain-specific tests were also used to evaluate the effectiveness of the intervention: Repeatable Battery for the Assessment of Neuropsychological Status (RBANS) memory subscores and TMT. Conversion to CATD was also evaluated. The intervention improved one of the two global measures of cognition (ADAS-Cog), but not the other (MMSE), and these results were sustained for 22 months post-intervention. One of the four domain-specific tests was significantly improved (RBANS immediate memory); RBANS delayed memory and TMT A and B were not significantly improved by the intervention. The author argues these null findings on the domain-specific tests over time support the case for their intervention to have a “true” impact and not merely a byproduct of attention or practice effects. In this small sample, half of the control or delayed intervention group converted to CATD during the 28-month followup, but none of the early intervention group converted to CATD. Even the trial authors are cautious to avoid overstating this finding, given the size of the study. FDG-PET was used to measure declines in brain glucose uptake as a marker of disease progression. People with MCI who received the intervention showed no decline in glucose uptake during the 6-month study period, while people with MCI who did not receive the intervention showed widespread declines in uptakes.

Another small trial randomized 19 participants to either a cognitive training intervention (n=9) or a no-intervention control group (n=10).^45^ The group intervention, which ran 2 hours per week for 6 weeks, involved a combination of coping skills education (moderating mood, sleep, relaxation) and training of specific memory techniques (chunking, categorization, cueing). Results from eight objective measures of memory and nine subjective measures of memory were reported. The objective memory measures included immediate and delayed word list, shopping list, names and faces, and paragraph. The nine subjective measures of memory originated from one tool, the Memory Functioning Questionnaire, and included self-reported present memory ability, frequency of forgetting, retrospective functioning, general functioning, perceived impact of memory functioning, seriousness, memory skill use, inevitable decline, and effort utility. No significant effects of training were seen at 6 months on the eight objective measures of memory. Participants in the intervention group self-rated their memory more positively than those in the control group at 6 months (1/9 subjective measures). For all eight reported test results, none of the analyses showed a positive Cohen’s D.

The Promoting Healthy Ageing with Cognitive Exercise (PACE) trial randomized 160 adults with MCI to a cognitive activity intervention or an educational control.^51^ Participants in the intervention and control arms met in small groups for 90 minutes, twice a week, for five weeks. The intervention arm received strategies specific to improving attention, processing speed, executive functioning, memory, and language. The educational (control) arm received information and participated in small group discussions about physical activity, stress, depression, sleep, and expectations for retirement. Participants in both arms received a telephone call at 6 months. Participants in the intervention arm completed 30 minutes of cognitive exercises prior to this booster call. Three measures of brief cognitive test performance/multidomain neuropsychological test performance (Consortium to Establish a Registry for Alzheimer’s Disease [CERAD] cognitive battery; MMSE; Cambridge Cognitive Examination-Revised), three measures of attention or processing speed (Digit Span, Symbol Search, TMT A), two measures of executive functioning (TMT B, Controlled Oral Word Association Test), and one measure of memory (California Verbal Learning Test- Second Edition) were used at baseline, after 1 year, and 2 years post-intervention. Only one of these nine assessments showed a slightly significant effect of the intervention (Digit Span Forward), which the authors state is of questionable clinical significance.

Kwok enrolled 223 adults over the age of 65 with “subjective memory complaints” but no identified dementia (>19 on the Chinese MMSE).^50^ The intervention used in the Kwok trial is based on the ACTIVE trial intervention and focused on the same three domains: attention/processing speed, memory, and reasoning. Training was conducted 1.5 hours per week for 12 weeks (twice as long as ACTIVE). The control condition was a health lecture each week for the same 12-week period. Assessments were conducted at baseline, and 12 weeks and 9 months post-intervention. Outcomes included: subjective memory complaints (Chinese Memory Symptom Scale) and brief cognitive test performance/multidomain neuropsychological test performance (Chinese versions of the MMSE and the Mattis Dementia Rating Scale battery). Overall, no significant improvements in cognition were found post-intervention or at 1 year, although some subgroup analyses by education level showed significance (training was more effective for those with less education).

The Herrera et al. trial is different from the other cognitive training trials targeting people with existing MCI because it is an individual, computer-based intervention.^46^ Twenty-two people with MCI were randomized to cognitive training or cognitive activity (control) 60 minutes, twice a week, for 12 weeks. The cognitive training involved a number of memory and attention training tasks on the computer, such as memorizing a group of pictures or a group of words spoken by the computer for later identification, or testing the time it took for participants to identify a target image. Participants in the control arm completed various computer-based cognitive activities including matching countries and capitals, organizing items into groups, finding similarities and differences, and reading comprehension. Verbal memory outcomes were assessed using the Digit Span, 12-word list recall (BEM-144), 16-item free and cued reminding test, and the memory subscore of the MMSE. Visual memory was assessed using Doors and People, DMS48 test, and the Rey-Osterrieth Complex Figure recall. The authors conceptualize these outcomes as recognition (Doors Recognition Sets A and B, DMS48), working memory (Digit Span Forward and Backward), and recall (BEM-144 12-word list, 16 item free and cued, MMSE-3 words, Rey Complex Figure). Results were mixed. One of three recognition tests improved at 6 months compared to control condition (Doors, Set A); one of two working memory tests improved (Digit Span Forward); and two of four recall tests improved (BEM-144 and MMSE). This small study showed remarkable results when analyzed with Cohen’s D. For six of the seven reported memory tests showed a positive Cohen’s D result. Effect sizes ranged between 1.9 and 3.1. Both of the tests in the executive, attention, processing speed category showed positive Cohen’s D results, with effect sizes up to 4.5.

## Interpreting the Findings

The overall results are summarized in Tables 4A.8 and 4A.9. The ACTIVE trial showed most clearly that cognitive training could improve performance on the domain being trained but there was little generalization to other cognitive domains. There was also no difference in dementia diagnosis at 5 years. There may be an IADL effect at 10 years but there was high attrition. CATD results are hard to interpret because the design was post hoc. Processing speed training was associated with IADL improvement (or less decline) but that benefit is not linked to dementia per se.

Table 4A.8 Summary of overall results of cognitive training for older adults with normal cognition

Author, Year | Domains Trained | Group/Individual | Computer/No Computer | Intensity | Testing Outcomes | Other Outcomes | Tools Used to Assess
Ball, 2002 ^ 25 ^ | Memory, reasoning, speed of processing | Group | Computer | 10–12 hours over 6 weeks, booster at 11 months | - Speed (only for Attn/Speed Arm, ES=.87); - Memory (only for Attn/Speed arm, ES=.17); - Reasoning (only for Reasoning Arm, ES=.26) | - NS Everyday problem solving; - NS IADL; - NS Everyday Speed Habits | - Memory (HVLT, RAVLT, and RBMT); - Reasoning (word series, letter series, letter sets); - Speed (DSST, Digit Symbol Copy, UFOV)
Wolinsky, 2013 ^ 47 ^ | Speed of processing | Individual | Computer | 10 hours over 5 weeks, booster at 11 months | - Speed (ES=.32–.58 depending on booster); - NS Executive (+ TMT A and B, SDMT, and Stroop-Word,; - NS Stroop-Color, COWAT or DVT) | None | - Speed (UVOF); - Executive (TMT A and B, SDMT, SCWT, COWAT, and the DVT)
Miller, 2013 ^ 42 ^ | Short- and long-term memory, language, visual spatial processing, reasoning, and calculation | Individual | Computer | 13 hours over 8 weeks | - Delayed memory; - NS Immediate memory; - NS language; - (Other domains not reported) | None | - Delayed (Delayed Buschke-Fuld, Delayed Rey-Osterrieth, VP); - Immediate (Buschke-Fuld Total, Rey-Osterrieth Copy, VP Total); - Language (FAS, Animal Naming, BNT)
Carretti, 2013 ^ 44 ^ | Working memory | Individual | Computer | 2.5–3.5 hours over 2 weeks (50–70 minutes per session, 3 sessions total) | - Delayed memory; - NS Immediate memory; - NS language; - (Other domains not reported) | - Listening comprehension (True/False, Map Drawing); - NS Reading Comprehension; - NS Fluid Intelligence | - Working Memory (Categorization Working Memory Span Test, Working Memory Updating Word Span Test); - Listening Comprehension (True/False Questions, Map Drawing); - Reading Comprehension (Adapted from Nelson-Denny Reading Test); - Fluid Intelligence (Cattell Culture Fair Test, Scale 3)
Klusmann, 2010 ^ 43 ^ | None, general computer instruction | Group | Computer | 112.5 hours over 6 months of in-class instruction | - Delayed Memory; - NS Immediate Memory; - NS Executive Attention; - NS Verbal Fluency | None | - Immediate and delayed story recall (RBMT); - Short and long delay free word recall (FCSRT); - Semantic verbal fluency; - Executive functioning (SCWT, TMT B/A)

Attn=attention; BNT=Boston Naming Test; COWAT=Controlled Oral Word Association Test; DSST=Digit Symbol Substitution Test; DVT=Digit Vigilance Test; ES=effect size; FAS=verbal fluency test using words starting with F, A, and S; FCSRT=Free and Cues Selective Reminding Test; HVLT=Hopkings Verbal Learning Test; IADL=instrumental activities of daily living; NS=no statistically significant difference; RAVLT= Rey Auditory Verbal Learning Test; RBMT=Rivermead Behavioral Memory Test; SCWT=Stroop Color Word Test; SDMT=Symbol Digit Modalities Test; TMT=Trail Making Test (Parts A & B); UFOV=Useful Field of View; VP=verbal proficiency

Table 4A.9 Summary of overall results of cognitive training for cognitively impaired older adults

Author, Year | Domains Trained | Group/Individual | Computer/No Computer | Intensity | Testing Outcomes | Other Outcomes | Tools Used to Assess
Buschert, 2012 ^ 48 ^ Forster, 2011 ^ 49 ^ | Mnemonic memory training | Group | No Computer | 12 hours over 6 weeks | - NS Global Cognition (+ ADAS-Cog, NS MMSE, ES=.26); - NS Immediate & Delayed Memory (+ immediate, NS delayed); - NS Executive/Attention | - Conversion to CATD; - Glucose uptake | - Brief cognitive test performance/Multidomain neuropsychological test performance (ADAS-Cog & MMSE); - Immediate & Delayed Memory (RBANS); - Executive/Attention (TMT A & B)
Kwok, 2012 ^ 50 ^ | Memory, reasoning, speed of processing | Group | No Computer | 18 hours over 12 weeks | - NS Attention; - NS Initiation/preservation; - NS Construction; - NS Conceptualization; - NS Memory | Subjective Memory Complaints (results not reported) | - Attention, initiation/preservation, construction, conceptualization, and memory (Domains from Chinese Mattis Dementia Rating Scale); - Subjective memory complaints (Chinese Memory Symptom Scale)
Rapp, 2002 ^ 45 ^ | Memory | Group | No Computer | 12 hours over 6 weeks | - NS Memory | Present self-rated memory improved | Word list (immediate and delayed). shopping list (immediate and delayed), names and faces (immediate and delayed), paragraph (immediate and delayed)
Vidovich, 2015 ^ 51 ^ | Attention, memory, executive processes | Group | No Computer | 15 hours over 5 weeks | - NS Global Cognition; - NS Memory; - NS Executive; - Attention or Processing (+ DS Forward, NS DS Backward, symbol search, and TMT B) | No differences in perception of memory | Brief cognitive test performance/Multidomain neuropsychological test performance (CERAD, MMSE, CAMCOG-R), Memory (CVLT-II), Attention or Processing (DS, Symbol Search, TMT B), executive (COWAT, TMT A)
Herrera, 2012 ^ 46 ^ | Memory, executive, attention, processing speed Note: authors classify as recognition, working memory and recall | Individual | Computer | 24 hours over 12 weeks | - Recognition (+ Doors Set A, NS Doors B and DSM48); - Working memory (+ DS Forward, NS DS Backward); - Working memory (+BEM-144 12-word list and MMSE 3 words, NS 16-Item free and cued and Rey Complex Figure) | NR | Recognition (Doors Recognition Sets A and B, DMS48), Working memory (DS Forward and Backward), Recall (BEM-144 12-word-list, 16-Item free and cued, MMSE-3 words, Rey Complex Figure)

ADAS-Cog=Alzheimer’s Disease Assessment Scale-Cognitive Subscale; BEM-44= Batterie d’Efficience Mnesique 144; CAMCOG-R=Cambridge Cognition Examination-Revised; CATD=clinical Alzheimer’s-type dementia; CERAD=Consortium to Establish a Registry for Alzheimer’s Disease; COWAT=Controlled Oral Word Association Test; CVLT-II=California Verbal Learning Test, Second Edition; DMS48=Delayed Matching-to-Sample Task; DS=Digit Span; ES=effect size; MMSE=Mini-Mental State Examination; NR=not reported; NS=no statistically significant difference; RBANS=Repeat Battery for the Assessment of Neuropsychological Status; TMT=Trail Making Test (A & B)

When reviewing the larger literature set, in contrast to the ACTIVE trial, most of the other studies showed mixed results; at times one test for a domain is significant and the other is not. A few studies show sustained improvement in the domain that was trained, similar to ACTIVE. The intensity of domain-specific training was relatively consistent (10–18 hours over 5–12 weeks). This extent of treatment seems to continue to show an effect 5–10 years later. The booster effect in ACTIVE is hard to assess because the sampling was not random. Effect sizes are mostly small; however, speed of processing effect sizes are larger.

Overall, the results are consistent with a theoretical base that assumes various areas of the brain can be trained to perform better (or lose ability less quickly) but this training has little effect on other areas.

* Note that the literature currently does not use the term CATD; we specified whenever the diagnosis of dementia was defined.