# 3 Search Results

Bibliographic database searches identified 9,448 unique references (Figure 3.1). Title and abstract screening of these yielded 1,116 references for full text review. Hand searching identified an additional 185 references yielding a total of 1,301 references for full text review. Full text review yielded 263 references eligible for our review. Common exclusion reasons included ineligible populations (n=320; e.g., individuals with dementia), ineligible study designs (n=188; i.e., nonexperimental designs), ineligible interventions (n=186; interventions not intended to prevent dementia), and inadequate followup time (n=224; followup less than 6 months). Appendix D provides a list of excluded studies and reasons for exclusions. Appendix E provides a list of prospective cohort studies related to health and aging topics that prompted special searches in an attempt to find relevant articles.

Figure 3.1 Literature flow diagram

Figure 3.1 is the literature flow diagram, which is also described in the text. It enumerates articles retrieved through the literature search, articles excluded, and articles retrieved through hand searching.

Studies were categorized and results analyzed by the intervention types addressed (Table 3.1). Several studies are grouped in multiple intervention types because they addressed more than one intervention type in multiple arms. As Table 3.1 shows, not all interventions expected per the protocol were informed by published studies.

Table 3.1 Eligible publications by intervention type

Report Intervention Type | Protocol Type | Eligible Articles
Cognitive interventions | Cognitive stimulation and training | 46
Physical activity/exercise | Physical activity | 48
Nutraceuticals | Nutraceuticals | 25
Diet types | Diet types | 9
Multimodal interventions | (No direct match to groups listed in original protocol) | 21
Hormone therapy | Hormone therapies | 44
Vitamins | Vitamin supplements | 29
Antihypertensive treatment | Cardiovascular and cerebrovascular disease treatments | 24
Lipid lowering treatment | Cardiovascular and cerebrovascular disease treatments | 10
Nonsteroidal anti-inflammatory drugs | Aspirin/NSAIDS | 8
Acetylcholinesterase inhibitors | Pharmacologic | 13
Diabetes medication treatment | Diabetes treatments | 8
Other interventions
Other drugs | Pharmacologic | 2
Social engagement | Social engagement | 2
Sleep disorder treatments | Sleep disorder treatments | 2
Music-based interventions | Music-based interventions | 2
Depression treatments | Depression treatments | 0
Obesity treatments | Obesity treatments | 0
Smoking cessation | Smoking cessation | 0
Community-level interventions | Community-level interventions | 0
| Brain stimulation | 1
TOTAL INTERVENTIONS | | 294
| Minus duplicates (publications in more than 1 intervention type) | −31
TOTAL PUBLICATIONS | | 263

NSAIDS=Nonsteroidal anti-inflammatory drugs