# 2 Methods

## Protocol Development

Because of the overall plan for the use of this review given by the National Institute on Aging (NIA) sponsor, this project follows a unique model. The role of the Key Informants was filled by the Committee on Preventing Dementia and Cognitive Impairment of the National Academies of Sciences, Engineering, and Medicine (The National Academies), which will use the report to help develop its own report to the NIA on the state of knowledge on the efficacy, comparative effectiveness, and harms of interventions to prevent or delay the onset of age-related cognitive decline, MCI, or CATD. (An overview of the National Academies’ conflict of interest policies can be found at http://nationalacademies.org/studyprocess/index.html; detailed information is available at http://www8.nationalacademies.org/cp/information.aspx?key=Conflict_of_Interest.) Because the National Academies Committee did not see the draft Key Questions, PICOTS, and analytic framework until the KQs were posted for public comment, a panel of content experts from federal agencies acted as proxy Key Informants prior to posting. The content experts were drawn from the NIA, the National Institute of Neurological Disorders and Stroke, the Department of Veterans Affairs, the Administration for Community Living, and the Centers for Disease Control and Prevention. There was not a separate, independent Key Informant panel. The role of the Technical Expert Panel was then filled by the National Academies Committee.

## Criteria for Inclusion/Exclusion of Studies in the Review

We included studies that met our inclusion criteria based upon the PICOTS framework outlined above and the study-specific inclusion criteria described in Table 2.1.

Table 2.1 Study inclusion criteria

Category | Criteria for Inclusion
Study Enrollment | For KQ1: Adults with normal cognition. For KQ2: Adults with MCI. For KQ3: Adults with normal or abnormal cognition who have had testing such as cognitive tests, blood/CSF testing, or brain imaging used in intervention studies in KQ1 or KQ2.
Study Objective | For KQ1: To test the efficacy, comparative effectiveness, and harms of interventions to prevent, delay, or slow cognitive decline, onset of MCI, or clinical Alzheimer’s-type dementia. For KQ2: To test the efficacy, comparative effectiveness, and harms of interventions to prevent, delay or slow clinical Alzheimer’s-type dementia. For KQ3: To examine the association between biomarker outcomes and incidence of MCI of clinical Alzheimer’s-type dementia.
Study Design | For KQ1–2: RCTs of any size and large prospective quasi-experimental cohort studies with comparator arms (n≥250 per arm). For KQ3: Studies identified in KQs 1 and 2
Outcomes | Cognitive performance measured with validated instruments, biomarker measures associated with clinical Alzheimer’s-type dementia, and incident MCI or clinical Alzheimer’s-type dementia (pure vascular dementia including strokes is excluded)
Timing | For KQ1–2: Minimum followup of 6 months for intermediate outcomes. For KQ3: No minimum followup.
Publication Type | Published in peer-reviewed journals and grey literature with full text available (if sufficient information to assess eligibility and risk of bias are provided).
Language of Publication | English

CSF=cerebrospinal fluid; KQ=Key Question; MCI=mild cognitive impairment; n=sample size; RCTs= randomized controlled trials

## Literature Search Strategies

We searched Ovid Medline, Ovid PsycINFO, Ovid Embase, and the Cochrane Central Register of Controlled Trials (CENTRAL) to identify randomized controlled trials (RCT), nonrandomized controlled trials, and prospective cohort studies published and indexed in bibliographic databases between January 2009 and September 2016. We identified eligible studies published prior to 2009 using the previous AHRQ review, including the excluded study bibliography.^13^ Our search strategy (Appendix A) included relevant medical subject headings and natural language terms for two concepts: 1) the [underlined: conditions] of dementia, MCI, cognitive decline, and 2) [underlined: interventions]—a wide variety of intervention types. These concepts were combined with filters for relevant intervention study designs. We supplemented bibliographic database searching with citation searches of recent relevant systematic reviews. To confirm that we identified all high-quality, quasi-experimental studies, we supplemented our bibliographic database search for potentially relevant publications using a list of longitudinal studies provided by the National Academies Committee. We will update searches while the draft report is under public/peer review.

A significant challenge to developing our bibliographic database search strategy was the wide variety of interventions that have been suggested to influence cognitive decline and the fact that many of these interventions have a primary purpose other than preventing this decline. Our search strategy to identify intervention studies with cognitive outcomes measured as secondary to the purpose of a given study must acknowledge the risk of identifying a biased set of studies because dementia results will be more likely noted in abstracts if they are positive. For example, intervention studies with the primary goal of reducing blood pressure or managing diabetes are more likely to mention cognitive outcomes in titles or abstracts when those results are significant. Therefore, our search strategy was more likely to identify studies with significant results and unlikely to identify all studies measuring cognitive outcomes. This issue is especially challenging when secondary outcomes may only be identified during a full text review. It was not feasible to screen the full text of all publications of studies evaluating any intervention suggested to benefit cognitive outcomes. To address this challenge, we revisited the larger evidence base for specific interventions where cognitive outcomes were likely secondary to the primary purpose of the intervention when synthesized results clearly suggested a benefit from that intervention to preventing cognitive decline.

Bibliographic database search results were downloaded to EndNote. Two independent investigators reviewed titles and abstracts to identify publications of studies potentially relevant to our inclusion criteria. Two investigators independently screened the full-text of those studies identified to determine if inclusion criteria were met. Differences in screening decisions were resolved by consultation between investigators, and, if necessary, consultation with a third investigator. Exclusion reasons for citations that underwent full-text screening were documented.

We searched grey literature sources to identify relevant completed and ongoing studies using ClinicalTrials.gov. These results were used to identify studies, outcomes, and analyses not reported in the published literature to assess publication and reporting bias and inform future research needs.

## Data Abstraction and Data Management

Studies meeting inclusion criteria were distributed among investigators for data extraction. We extracted author, year of publication, population, intervention, comparison, outcomes, timing, and setting. Results were extracted from studies assessed as having low to moderate risk of bias. Summary tables were created and reviewed by a second investigator, checking for accuracy.

## Assessing Methodological Risk of Bias of Individual Studies

We created an instrument to assess risk of bias components specific to study design to assess risk of bias of eligible studies based upon AHRQ guidance (Appendix B).^17^ Relevant components included participant selection, method of randomization or selection, blinding, allocation concealment, and attrition. Two investigators independently assessed risk of bias for all eligible studies and consulted with each other to reconcile discrepancies in overall risk of bias. Overall risk of bias assessments for each study were classified low, moderate, or high based on the collective risk of bias inherent in each domain and confidence that the results were believable given study limitations.

## Data Synthesis

We summarized results in summary tables, excluding studies with high risk of bias and synthesized the evidence for each unique population, intervention, comparison, and outcome and harm. We organized evidence tables and results by intervention type and the population addressed. Subgroups, where possible, were examined and reported separately.

We reported summary results for primary and intermediate outcomes and harms. Intermediate cognitive outcomes were assessed using neuropsychological tests or biomarker measurements in the literature. Because studies used a highly varied set of tests, we grouped them into categories to facilitate analysis. We categorized neuropsychological tests by their purpose and/or what they attempt to measure, such as specific cognitive domains (e.g., executive function, memory) (Appendix C) for extraction and analysis. Since cognitive interventions were specifically targeting cognitive functions, we reported on a more complete set of cognitive domains for cognitive interventions. The wide variety on inconsistency of tests used made it difficult to summarize the findings and prevented meta-analysis. For the cognitive training component we did use Cohen’s D where possible.

Changes in neuropsychological test scores can vary in clinical significance. While cognitive function declines as we age, it can be challenging to identify a level of change that is concerning. Reliable change indices have been suggested for many commonly used instruments assessing cognitive function. These serve to provide a benchmark of meaningful change in the test scores for individuals.^18^ Methods for calculating reliable change indices ensure that the degree of change is not due to chance or measurement error; later refined to also account for practice effects, and regression to the mean.^18^ [underlined: However, such scores were not developed to assess meaningful differences between groups of individuals, the comparisons of interest to systematic reviewers.] We identified published reliable change indices for many commonly used instruments (Appendix C) and used these to facilitate interpretation of statistically significant results. For outcomes measured with instruments lacking established thresholds to measure improvement, we calculated standard effect sizes and required a small effect size (d ≥0.2) to conclude efficacy or comparative effectiveness. Effect sizes were calculated using STATA 14/SE (Stata).^19^ We assessed clinical and methodological heterogeneity and variation in effect size to determine appropriateness of pooling data.^20^ Clinical and methodological heterogeneity precluded quantitative pooling of results.

## Assessing the Strength of Evidence for Major Comparisons and Outcomes

When sufficient data were available (more than one study or one large study [n ≥500]), the overall strength of evidence for select outcomes within each comparison were evaluated based on five required domains: 1) study limitations (risk of bias); 2) directness (single, direct link between intervention and outcome); 3) consistency (similarity of effect direction and size); 4) precision (degree of certainty around an estimate); and 5) reporting bias.^21^ Study limitations were rated as low, medium, or high based on study design and the risk of bias of eligible studies in a particular evidence base (comparison). Consistency was rated as consistent, inconsistent, or unknown/not applicable (e.g., single study) based on whether intervention effects were similar in direction and magnitude, and statistical significance of all studies. Directness was rated as direct or indirect based on whether inference required observations across studies. That is, more than one step between the intervention and the outcome of interest was needed to reach the conclusion. For instance, a medication that lowers blood pressure might affect dementia risk by first lowering blood pressure. The reduced blood pressure may then lower the risk of dementia. This relationship is indirect. However, if a medication directly lowers dementia risk without acting through altering a risk factor such as blood pressure, the relationship would be direct. Indirectness can also occur when the study uses a shorter followup time to test a relationship. Such evidence may help formulate a potential linkage, but it does not test it directly. Precision was rated as precise or imprecise based on the degree of certainty surrounding each effect estimate or qualitative finding. An imprecise estimate is one for which the confidence interval is wide enough to include clinically distinct conclusions. For outcomes found to have at least moderate or high strength of evidence, we assessed reporting bias by evaluating the potential for publication bias, selective outcome reporting bias, and selective analysis reporting bias by comparing reported results with those mentioned in the methods section and assessment of the grey literature to assess potentially unpublished studies. Publication bias is more easily addressed for RCTs than observational studies by searching for registered trials using sources like ClinicalTrials.gov. (However, we did not identify any observational studies to include.) Other factors we considered in assessing strength of evidence include the presence of a dose-response relationship, the presence of confounders, and the strength of the association.

Assessing strength of evidence for studies with null findings is especially challenging because several strength of evidence are designed to address differences. Although it is important to assess the strength of evidence for negative (no effect) findings, it is hard to assess effect size when there is no effect. We tried to separate statements about the scientific quality of the evidence from those addressing the nature of the findings themselves. Due to the large number of comparisons with null findings (i.e. intervention and comparison yielded results that were not statistically different from each other), we assessed strength of evidence and formulated results cautiously. When assessing precision, it was important to identify the level of precision that provided confidence of no effect.

Based on these factors, the overall strength of evidence for each outcome from a given intervention was rated as:

- High: Very confident that estimate of effect lies close to true effect. Few or no deficiencies in body of evidence, findings believed to be stable.
- Moderate: Moderately confident that estimate of effect lies close to true effect. Some deficiencies in body of evidence; findings likely to be stable, but some doubt.
- Low: Limited confidence that estimate of effect lies close to true effect; major or numerous deficiencies in body of evidence. Additional evidence necessary before concluding that findings are stable or that estimate of effect is close to true effect.
- Insufficient: No evidence, unable to estimate an effect, or no confidence in estimate of effect. No evidence is available or the body of evidence precludes judgment.

An overall rating of high strength of evidence would imply that the included studies were RCTs with a low risk of bias, with consistent, direct, and precise domains. We assessed strength of evidence for key final health outcomes measured with validated scales.

Tables presenting summary strength of evidence for conclusions drawn from the data synthesis are provided in each Results chapter that had at least one intervention type with sufficient evidence to arrive at a strength-of-evidence rating. Tables were not created for intervention types for which all outcomes for the intervention type for a given population (adults with normal cognition or adults with MCI) was either too limited (only one study with fewer than 500 participants) or nonexistent.

## Assessing Applicability

Applicability of studies was determined according to the PICOTS framework. Study characteristics that were evaluated to assess applicability included, but were not limited to, the population from which the study participants were enrolled, narrow eligibility criteria, baseline cognitive function, and patient and intervention characteristics different than those described by population studies.^22^ Here again data were frequently missing or implied. For example, baseline cognitive status was not consistently or precisely assessed in many instances. Applicability issues are addressed in Chapter 5.

## Peer Review and Public Commentary

Experts in dementia and systematic reviews were invited to provide external peer review of this systematic review; AHRQ and an associate editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We addressed all reviewer comments, revising the text as appropriate, and documented everything in a disposition of comments report that will be made available after AHRQ posts the final systematic review on the Effective Health Care Web site.