# 1 Introduction

## Background

Dementia severely erodes individuals’ functioning and quality of life, creates burden and stress on the entire family, and is a major predictor of institutionalization. Although the age and sex standardized prevalence of dementia and the rates of incident dementia have fallen over the last several decades,^1, 2^ the number of U.S. adults over 70 with dementia and mild cognitive impairment is rising.^3, 4^

Additionally, dementia-related costs are high, exceeding even those of heart disease and cancer, and are often paid directly by families.^5^ Given such enormous family and societal burdens, identifying interventions with potential to prevent or delay the onset of dementia is an urgent public health priority. Although many putative risk factors have been identified, the challenge is to identify any interventions that can lead to reductions in dementia incidence and make them more widespread.

## Cognitive Impairment

### Dementia—Definitions and Diagnostics

Research on dementia has been affected by changes in nomenclature and classification. Most published work was done under the Fourth Edition of the Diagnostic Statistical Manual of Mental Disorders (DSM-4), but the Fifth Edition (DSM-5) published in 2013 made substantive changes to the language describing cognitive impairment. It laid out a set of six distinct neurocognitive domains, some of which are associated with specific parts of the brain. These changes can affect the way various elements of dementia are diagnosed and viewed. Other tests, such as blood tests or radiologic images, are often performed to rule out different diagnoses. The term dementia is slowly being replaced by the DSM-5 defined phrase “major neurocognitive disorder,” which is more inclusive than dementia. For example, the earlier definition of dementia excluded those with only loss of ability to express or understand speech due to a stroke, while DSM-5 would include such individuals in its more broadly defined syndrome.

Even beyond the shift from DSM-4 to DSM-5, the terminology used to discuss dementia and cognitive impairment is inconsistent and changing. Several criteria have been used to diagnose dementia (typically dementia-causing diseases), including criteria described by the National Institute of Neurological and Communicative Disorders and Stroke (NINCDS) and the Alzheimer’s Disease and Related Disorders Association (ADRDA) in 1983.^6^ More recently, the National Institute on Aging (NIA) and the Alzheimer’s Association jointly issued criteria and guidelines.^7^ Specific etiologies of neurocognitive disorders include Alzheimer’s disease and other less common conditions (e.g., frontotemporal lobar degeneration, Lewy body disease, traumatic brain injury, etc.).^8^ Diagnosis of a neurocognitive disorder due to Alzheimer’s disease requires steadily progressive cognitive decline, generally with early predominant impact on the cognitive domain of learning and memory, from a previous level occurring outside the context of delirium not better explained by other mental disorders. If the decline interferes with independence in everyday activities, it is classified as major; if not, mild. Other tests, such as blood tests or radiologic images, are often performed to rule out different diagnoses. For this report, the term clinical Alzheimer’s-type dementia (CATD) is used to recognize the clinical reality that a precise diagnosis of Alzheimer’s disease is rarely available and clinicians are often working with patients with dementia from some unknown mix of etiologies. This term (CATD) is designed to be inclusive but does exclude several other forms of dementia (such as Lewy body disease or infectious disease; see Table 1.1), including some that can otherwise be well-identified). Note that the literature currently does not use the term CATD; we specified whenever the diagnosis of dementia was defined.

Table 1.1 DSM-5 underlying causes of major neurocognitive disorders

Cause
Frontotemporal lobar degeneration
Lewy body disease
Traumatic brain injury
Substance/medication use
HIV infection
Prion disease
Parkinson’s disease
Huntington’s disease
Another medical condition
Alzheimer’s disease
Vascular disease
Multiple etiologies
Unspecified

Source: American Psychiatric Association (2013). Neurocognitive Disorders. Diagnostic and Statistical Manual of Mental Disorders, Fifth Edition. Arlington, VA, American Psychiatric Association.

Italicized causes are outside the scope of this review.

### Age-Related Cognitive Decline and Mild Cognitive Impairment—Definitions and Diagnostics

Some subtle decline in cognition associated with aging is considered normal or inevitable, particularly for people past the age of 60 years. For example, reaction time and speed of processing are known to decline slowly throughout adulthood Therefore, greater difficulty learning new information by 70 or 80 years old may not necessarily be a warning sign of neurocognitive disease in the absence of other signs or symptoms of cognitive difficulty.

If the extent of decline crosses a threshold (variously defined), the individual is said to have some intermediate form of cognitive impairment. One way of defining this threshold is when the decline in cognition is recognized by an individual, caregiver, or health professional and requires the individual to compensate using tools such as lists, maps, or pill boxes to continue to perform daily activities. Another way cognitive decline has been defined is based upon formal cognitive testing scores below norms for younger populations, even if there are no changes in function. After a variety of terms were proposed for such early or minimal changes in cognition, in 1988 the term mild cognitive impairment (MCI) was coined which compares an individual’s cognitive performance against same-aged normative samples.^9^ Roughly half of people with MCI will progress to a more severe form of cognitive decline over about 3 years.^10^ The relationship between progression from overall cognitive decline to dementia is less clear.

Petersen’s criteria are typically used to diagnose MCI as characterized by a subjective decline in cognition and objective neurological testing threshold without a loss of function. MCI corresponds to mild neurocognitive disorder in the DSM-5.^11^ In contrast, cognitive aging that is the process of normal changes that occur as individuals age is called age-related cognitive decline and is highly variable.^12^

### Distinguishing Between Mild Cognitive Impairment and Dementia

A separate Institute of Medicine (IOM) committee (not connected with this study) has recently recognized potential problems with using cognitive and functional decline elements of the definition for dementia and MCI.^12^ They note, “The natural history that leads to Alzheimer’s-type dementia could be summarized as follows: persons with normal cognition start developing deterioration in their cognitive performance of slow onset and progression. When this deterioration achieves a ‘clinically significant’ level of cognitive deterioration that is documented objectively, this level of deterioration may be called cognitive impairment. This cognitive impairment may or may not be accompanied by subjective cognitive complaints. If the cognitive impairment is not accompanied by significant functional impairment (i.e., persons can live independently despite cognitive impairment), the cognitive impairment can be termed mild cognitive impairment or cognitive impairment without dementia. If deterioration in cognitive performance continues to the point where a person cannot maintain independent function, the cognitive impairment is called dementia. Given this natural history, cognitive performance is recognized as a patient-centered outcome.” The problem with using such criteria to define dementia and MCI is that functional impairment depends on social factors independent of the underlying disease causing cognitive impairment. Recognizing and measuring cognitive and functional decline depend upon the life-circumstances of the individual and the source of information about cognitive and functional performance (e.g., self, caregiver, and employer). For example, minor forgetfulness for a retiree may have less impact on function and be reported differently than it would for the same person still in in a cognitively challenging workplace. Likewise, modest loss of numeric skills may be unreported and insignificant for many older adults, but catastrophic for a scientist or an accountant.

### Causes of Cognitive Impairment

Dozens of specific diseases can cause major neurocognitive disorder (Table 1.1). Alzheimer’s disease is the most common diagnosis in this set, but persons with dementia may experience several types simultaneously. Individuals who meet the clinical criteria for Alzheimer’s disease are more likely than others to have certain genetic markers, patterns on brain imaging (e.g. atrophy), specific types of protein accumulation in the brain, or abnormal appearance of brain cells examined at autopsy. Yet, the relationship between these findings and measures of cognition are inconsistent and not constant. We do not know whether some of the biological changes underlying laboratory or imaging findings are causes of or caused by Alzheimer’s disease. This type of uncertainty greatly complicates efforts to prevent or slow impairments in cognition that are a prelude to Alzheimer’s disease. In this report, we use the term CATD to exclude most of the conditions italicized in Table 1.1.

## Interventions To Prevent or Slow Cognitive Decline

### Interventions and Underlying Theories

A number of reviews have assessed the evidence of the relationships between risk and protective factors and/or cognitive decline, MCI, and CATD, including the 2015 Institute of Medicine report on cognitive aging cited above^12^ and a 2010 Agency for Healthcare Research and Quality (AHRQ) systematic review.^13^ Several risk factors are correlated with incident CATD, some modifiable and others not. Nonmodifiable risk factors include age, sex, race/ethnicity, and family history. Certain medical conditions are associated with an increased risk of developing MCI and CATD, including depression, cancer, cardiovascular disease, diabetes, delirium, thyroid disorders, chronic kidney disease, and loss of hearing and/or vision. Modifiable risk or protective factors may include diet, physical activity, education and intellectual engagement, social engagement, alcohol, smoking, and substance abuse, medications, and vitamins. Interventions represent one way to establish the veracity of risk factors. If changing a putative risk factor changes the cognitive course, it will be seen as more salient. Interventions have been developed to address chronic disease status and modifiable risk factors as well as protective factors. Table 1.2 lists a number of interventions that have either been explored or suggested. More comprehensive intervention programs address multiple risk factors simultaneously with multi-domain interventions with components addressing nutrition, physical activity, cognitive training, social activity, and/or vascular risk factor management.^14^

Table 1.2 Interventions aimed at preventing age-related cognitive decline, MCI, and/or CATD

Interventions (Examples)
Aspirin/nonsteroidal anti-inflammatory drugs (NSAIDS)
Cardiovascular and cerebrovascular disease treatments (medications and nonpharmacologic interventions)
Cognitive stimulation and training
Community-level interventions (built environment)
Depression treatments (medications and nonpharmacologic interventions)
Diabetes treatments (medications and nonpharmacologic interventions)
Diet Types (Mediterranean, low fat, vegetarian, etc.)
Hormone therapies (estrogen, selective estrogen receptor modulators, testosterone)
Music-based interventions (dancing, playing music)
Nutraceuticals (gingko biloba, fish oil)
Obesity treatments (medications and nonpharmacologic interventions)
Pharmacologic (statins, cholinesterase inhibitors, nicotine)
Physical activity (aerobic, resistance training, balance, dancing)
Sleep disorder treatments (medications and nonpharmacologic interventions)
Smoking cessation
Social engagement (network, social activities)
Vitamin supplements (multivitamins, vitamin B, vitamin D)

MCI=Mild Cognitive Impairment; CATD=Clinical Alzheimer’s-Type Dementia

Interventions cannot change nonmodifiable risk factors. However, age, sex, race/ethnicity, and family history are relevant to intervention effectiveness because they can modify the effect of interventions. Further, provider perceptions of and attitudes toward nonmodifiable risk factors may themselves be modifiable. Genetic factors (i.e., ApoE status) have been shown to modify the degree to which risk factors and interventions correlate with cognitive decline.^12^

Theories justifying various interventions to slow or prevent cognitive decline are diverse. If cognitive decline is due to natural age-related degeneration of the brain, the theory of neuroplasticity suggests that cognitive training could be useful to stimulate the brain to build additional pathways and retain existing ones to build brain reserve against future decline. If brain degeneration and cognitive decline are due to toxins or lack of specific nutrients, changes in diet or nutritional supplements could be effective. If adequate blood flow to the brain is important in preventing cognitive decline, then medications and exercise that stimulate and maintain the health of the vascular system are reasonable. If inflammation is part of the process, antiinflammatory drugs may be effective. These theories support prevention trials testing cognitive training, physical exercise, cardiovascular and other medications, diets, and nutraceuticals (products derived from food sources that are purported to provide extra health benefits).

Preventive efforts can target any time point on the cognitive spectrum, which spans from healthy cognition to the normal age-related cognitive decline that everyone experiences to abnormal and subclinical cognitive decline to MCI, and finally, to dementia.

Research participants seeking to slow or prevent age-related cognitive decline, MCI, and CATD may have more than one risk factor. CATD may result from cumulative and possibly synergistic effects. Interventions may address one or multiple possible mechanisms with complex or multiple prevention strategies. Differential effects of interventions on subgroups defined on the basis of cumulative risk factors (both modifiable and nonmodifiable) may be of concern. Many studies testing the association of preventive factors or effectiveness of interventions for preventing dementia have looked at only the one-to-one relationship with a single risk factor or intervention. Rarely have studies used multidomain interventions, and potentially none have explored the possibility of cumulative or synergistic effects.

### Methods To Measure Intervention Impact—Measuring Cognitive Function and Biomarkers

Timing and measurement choices affect cognitive decline prevention studies. Researchers can recruit participants at any point along the cognitive continuum. Various proposed strategies target young and middle-aged adults with no evidence of cognitive decline, older adults worried about age-related changes, people with documented MCI, and those with major neurocognitive disorders. Common diseases that cause cognitive decline, especially CATD, progress slowly. Lengthy time periods are required between an intervention and the expectation of measurable cognitive decline or function in those not receiving an effective preventive intervention; the younger the participant, the longer the latency period. Short-term benefits on cognitive tests or biomarker measures are uncertain predictors of long-term effects on cognition.

Proof that an intervention prevents or delays MCI or dementia ideally includes evidence that the intervention led to fewer individuals with a subsequent diagnosis of MCI or CATD. Such measures are rarely possible, due to the extended study length required (i.e., >10 years) or the extremely large number of participants (i.e., thousands) required plus the complexity of measuring both cognition and functional abilities. Over shorter terms and in smaller studies, changes in cognitive function are assessed using validated neurocognitive tests addressing various domains of cognition. The range of testing includes both simple tests performed in a primary care clinic (such as drawing a clock face and remembering three words) and hours-long, comprehensive cognitive testing performed by a neuropsychologist measuring multiple domains of cognition.^15^

To assess changes in brain functional abnormalities earlier or with greater sensitivity than is possible with behavior-based testing or interviews, a variety of laboratory and brain imaging tests are used to look for changes in specific biologic substances, structures, or processes; collectively these are called biomarkers. Examples include total brain and hippocampal volumes; white matter hyperintensity volume;^16^ uptake with fluorodeoxyglucose positron emission tomography (PET) in key areas of the brain (e.g., temporomedial lobes); accumulation of brain amyloid ascertained with brain PET; and cerebrospinal fluid levels of tau, phosphorylated-tau, and amyloid beta.

Improvement or a slower deterioration from baseline of specific biomarker measures could indicate a slowing of age- or disease-related decline as a result of an intervention, to the extent that the biomarker is an accurate reflection of brain capacity and activity. As noted before, there is a good deal of inconsistency regarding the relationships between biomarkers. However, many studies have included or focused on measures of biomarkers and cognitive function.

## Scope and Key Questions

This systematic review is focused on intervention studies that target populations who are cognitively normal or may have age-related changes or MCI but do not yet have dementia. With the focus on CATD, the review does not include forms of dementia with multiple other causes, e.g., Lewy body, infectious diseases, frontotemporal, and traumatic brain injury (see the italicized conditions in Table 1.1). The review does include studies addressing vascular components of mixed dementia, but clear post-stroke dementia is out of scope. Intermediate outcomes such as measures of biomarkers and cognitive performance are included. However, since the review is focused on prevention, studies must be of at least 6 months duration to demonstrate some level of sustainability of the intervention effects. It is important to note that this duration requirement by necessity leaves out many short-term studies in this field.

### Key Questions

The review addresses two Key Questions (KQs) and the PICOTS (populations, interventions, comparisons, outcomes, timing, and setting) framework that address the effects of interventions for delaying or slowing age-related cognitive decline and preventing, delaying, or slowing MCI and clinical Alzheimer’s-type dementia (Table 1.3). The third KQ addresses the strength of association between various intermediate outcomes (e.g. biomarkers) with MCI and CATD.

Table 1.3 Populations, interventions, comparators, outcomes, timing, and settings (PICOTS)

PICOTS | KQ 1 | KQ 2 | KQ 3
Population | Adults with normal cognition | Adults with MCI | Adults with normal cognition or MCI
Intervention | Interventions aimed at preventing, delaying, or slowing the development of age-related cognitive decline, incident MCI or CATD | Interventions aimed at preventing, delaying, or slowing the development CATD | The analysis will be limited to intermediate outcomes uncovered in KQs 1–2
Comparators | Placebo Usual care Waitlist Information or attention control Active control | Placebo Usual care Waitlist Information or attention control Active control | NA
Outcomes | Final health or patient-centered outcomes: normal cognition, age-related cognitive decline, incident MCI or CATD (includes vascular or mixed dementia incidence but not post-stroke dementia incidence) Intermediate outcomes: Biomarker protein level(s) Cognitive test results Brain matter volume Brain cell activity level [underlined: As determined by:] Blood/CSF tests, Validated cognitive test results, and Brain scans Structural imaging - CT, MRI, PET Functional Imaging – PET, fMRI Molecular imaging – PET, fMRI, SPECT Adverse effects of intervention(s): Pharmacologic side effects, Psychological, Financial, Physical | Final health or patient-centered outcomes: Incident CATD (includes vascular or mixed dementia incidence but not post-stroke dementia incidence) Intermediate outcomes: Biomarker protein level(s) Cognitive test results Brain matter volume Brain cell activity level [underlined: As determined by:] Blood/CSF tests, Validated cognitive test results, and Brain scans Structural imaging - CT, MRI, PET Functional Imaging – PET, fMRI Molecular imaging – PET, fMRI, SPECT Adverse effects of intervention(s): Pharmacologic side effects, Psychological, Financial, Physical | Final health or patient-centered outcomes: Incident MCI or CATD (includes vascular or mixed dementia incidence but not post-stroke dementia incidence)
Timing | Minimum followup of 6 months for intermediate outcomes | Minimum followup of 6 months for intermediate outcomes | None
Settings | Community-dwelling adults, including assisted living | Community-dwelling adults, including assisted living | Community-dwelling adults, including assisted living

CATD=clinical Alzheimer’s-type dementia; CSF=cerebrospinal fluid; CT=computerized tomography; fMRI=functional magnetic resonance imaging; KQ=Key Question; MCI=mild cognitive impairment; MRI=magnetic resonance imaging; NA=not applicable; PET=positron emission tomography; SPECT=single photon emission computed tomography

KQ 1 In adults with normal cognition, what are the effectiveness, comparative effectiveness, and harms of interventions for:
  i. Delaying or slowing age-related cognitive decline?
  ii. Preventing, delaying, or slowing the onset of MCI?
  iii. Preventing, delaying, or slowing the onset of clinical Alzheimer’s-type dementia?
  a. Do effectiveness, comparative effectiveness, and harms of interventions differ as a function of patient characteristics (i.e., age, sex, race/ethnicity, family history, education, socioeconomic status, risk factor status)?
KQ 2 In adults with MCI, what are the effectiveness, comparative effectiveness, and harms of interventions for preventing, slowing, or delaying the onset of clinical Alzheimer’s-type dementia?
  a. Do effectiveness, comparative effectiveness, and harms of interventions differ as a function of patient characteristics (i.e., age, sex, race/ethnicity, family history, education, socioeconomic status, risk factor status)?
KQ 3 What is the strength of association between outcome measures examined in KQs 1 or 2 including (but not limited to) cognitive test results, biomarkers, and brain imaging results and the incidence of MCI or clinical Alzheimer’s-type dementia?

### Analytic Framework

Figure 1.1 is a traditional analytic framework, illustrating the relationship of intermediate and final outcomes. It should be noted, however, that the outcomes listed as intermediate may be measured at several times over an extended period and several themselves contribute to the diagnosis of MCI or CATD.

Figure 1.1 Analytic framework for interventions to prevent cognitive decline, mild cognitive impairment, and clinical Alzheimer’s-type dementia

CSF=cerebrospinal fluid; KQ=Key Question

Figure 1.1 is the analytical framework describing the flow of adults with normal cognition or adults with MCI who receive interventions to prevent age-related cognitive decline, MCI, or clinical Alzheimer’s-type dementia. These patients enter the system and receive a medication or combination of medications or other nonpharmacologic interventions. Preventive interventions can have associated harms. Intermediate outcomes include stability or increase in biomarker protein levels in blood/CSF, stability or decrease in cognitive test results, stability or decrease in brain matter volumne, or stability or decrease in brain cell activity. Final health outcomes include normal cognition, age-related cognitive decline, MCI, or clinical Alzheimer’s-type dementia. Baseline characteristics such as age, sex, race/ethnicity, family history, education level, modifiable risk factor status, and number of fisk factors may influence the observed outcomes.

## Report Organization

This report is organized in several chapters. Following the Methods chapter, we present the overall search results in Chapter 3 and syntheses conducted for each class of prevention interventions in Chapters 4A through 4M. Chapter 4A presents the systematic review of literature for cognitive training, Chapter 4B for physical activity interventions, and so on through Chapter 4M for other interventions. Since the introduction and the methods used applied to all the interventions, we present that material in separate chapters rather than duplicating them in each results chapter. Each of Chapters 4A through 4M presenting results is otherwise intended to stand on its own; therefore, each includes discussions specific to the intervention of interest. Next, Chapter 4N provides information on the linkages between biomarkers, cognitive performance, and incident MCI or dementia. The report finishes with a discussion of overarching themes (Chapter 5), overall conclusions with a summary of key findings (Chapter 6), and suggested future research (Chapter 7).