# Appendix S Biomarkers

Appendix Table S1 Relationship between biomarkers and cognitive performance and incidence outcomes in adults with normal cognition

Appendix Table S2 Relationship between biomarkers and cognitive performance and incidence outcomes in adults with MCI

## References for Appendix S

1 Witte AV, Kerti L, Hermannstadter HM, . Long-chain omega-3 fatty acids improve brain function and structure in older adults. Cerebral Cortex. 2014 Nov;24(11):3059–68. doi: http://dx.doi.org/10.1093/cercor/bht163. PMID: 23796946.23796946
2 Witte AV, Kerti L, Margulies DS, . Effects of resveratrol on memory performance, hippocampal functional connectivity, and glucose metabolism in healthy older adults. Journal of Neuroscience. 2014 Jun 4;34(23):7862–70. doi: http://dx.doi.org/10.1523/JNEUROSCI.0385-14.2014. PMID: 24899709.24899709
3 Coker LH, Hogan PE, Bryan NR, . Postmenopausal hormone therapy and subclinical cerebrovascular disease: the WHIMS-MRI Study. Neurology. 2009 Jan 13;72(2):125–34. doi: 10.1212/01.wnl.0000339036.88842.9e. PMID: 19139363.19139363
4 Resnick SM, Espeland MA, An Y, . Effects of conjugated equine estrogens on cognition and affect in postmenopausal women with prior hysterectomy. J Clin Endocrinol Metab. 2009 Nov;94(11):4152–61. doi: 10.1210/jc.2009-1340. PMID: 19850684.19850684
5 Resnick SM, Espeland MA, Jaramillo SA, . Postmenopausal hormone therapy and regional brain volumes: the WHIMS-MRI Study. Neurology. 2009 Jan 13;72(2):135–42. doi: 10.1212/01.wnl.0000339037.76336.cf. PMID: 19139364.19139364
6 Espeland MA, Rapp SR, Shumaker SA, . Conjugated equine estrogens and global cognitive function in postmenopausal women: Women’s Health Initiative Memory Study. JAMA. 2004 Jun 23;291(24):2959–68. doi: 10.1001/jama.291.24.2959. PMID: 15213207.15213207
7 Shumaker SA, Legault C, Kuller L, . Conjugated equine estrogens and incidence of probable dementia and mild cognitive impairment in postmenopausal women: Women’s Health Initiative Memory Study. JAMA. 2004 Jun 23;291(24):2947–58. doi: 10.1001/jama.291.24.2947. PMID: 15213206.15213206
8 Rapp SR, Espeland MA, Shumaker SA, . Effect of estrogen plus progestin on global cognitive function in postmenopausal women: the Women’s Health Initiative Memory Study: a randomized controlled trial. Jama. 2003 May 28;289(20):2663–72. doi: 10.1001/jama.289.20.2663. PMID: 12771113.12771113
9 Douaud G, Refsum H, de Jager CA, . Preventing Alzheimer’s disease-related gray matter atrophy by B-vitamin treatment. Proc Natl Acad Sci U S A. 2013 Jun 4;110(23):9523–8. doi: 10.1073/pnas.1301816110. PMID: 23690582.23690582
10 de Jager CA, Oulhaj A, Jacoby R, . Cognitive and clinical outcomes of homocysteine-lowering B-vitamin treatment in mild cognitive impairment: a randomized controlled trial. Int J Geriatr Psychiatry. 2012 Jun;27(6):592–600. doi: 10.1002/gps.2758. PMID: 21780182.21780182
11 Smith AD, Smith SM, de Jager CA, . Homocysteine-lowering by B vitamins slows the rate of accelerated brain atrophy in mild cognitive impairment: a randomized controlled trial. PLoS One. 2010;5(9):e12244. doi: 10.1371/journal.pone.0012244. PMID: 20838622.20838622
12 Tendolkar I, Enajat M, Zwiers MP, . One-year cholesterol lowering treatment reduces medial temporal lobe atrophy and memory decline in stroke-free elderly with atrial fibrillation: evidence from a parallel group randomized trial. Int J Geriatr Psychiatry. 2012 Jan;27(1):49–58. doi: 10.1002/gps.2688. PMID: 21308791.21308791
13 Seaquist ER, Miller ME, Fonseca V, . Effect of thiazolidinediones and insulin on cognitive outcomes in ACCORD-MIND. J Diabetes Complications. 2013 Sep–Oct;27(5):485–91. 10.1016/j.jdiacomp.2013.03.005. PMID: 23680059.23680059
14 Launer LJ, Miller ME, Williamson JD, . Effects of intensive glucose lowering on brain structure and function in people with type 2 diabetes (ACCORD MIND): a randomised open-label substudy. Lancet Neurol. 2011 Nov;10(11):969–77. doi: 10.1016/S1474-4422(11)70188-0. PMID: 21958949.21958949
15 Forlenza OV, Diniz BS, Radanovic M, . Disease-modifying properties of long-term lithium treatment for amnestic mild cognitive impairment: randomised controlled trial. Br J Psychiatry. 2011 May;198(5):351–6. doi: 10.1192/bjp.bp.110.080044. PMID: 21525519.21525519
16 Buschert VC, Giegling I, Teipel SJ, . Long-term observation of a multicomponent cognitive intervention in mild cognitive impairment. Journal of Clinical Psychiatry. 2012 Dec;73(12):e1492–8. doi: http://dx.doi.org/10.4088/JCP.11m07270. PMID: 23290333.23290333
17 Forster S, Buschert VC, Teipel SJ, . Effects of a 6-month cognitive intervention on brain metabolism in patients with amnestic MCI and mild Alzheimer’s disease. Journal of Alzheimer’s Disease. 2011;26 Suppl 3:337–48. doi: http://dx.doi.org/10.3233/JAD-2011-0025. PMID: 21971473.21971473
18 Suzuki T, Shimada H, Makizako H, . A randomized controlled trial of multicomponent exercise in older adults with mild cognitive impairment. PLoS One. 2013;8(4):e61483. doi: 10.1371/journal.pone.0061483. PMID: 23585901.23585901
19 Suzuki T, Shimada H, Makizako H, . Effects of multicomponent exercise on cognitive function in older adults with amnestic mild cognitive impairment: a randomized controlled trial. BMC Neurol. 2012;12:128. doi: 10.1186/1471-2377-12-128. PMID: 23113898.23113898