# Appendix R Other Interventions

Appendix Table R1 Characteristics of eligible studies: other interventions in adults with normal cognition

Appendix Table R2 Summary risk of bias assessments: other interventions in adults with normal cognition and MCI

## References for Appendix R

1 Newhouse P, Kellar K, Aisen P, . Nicotine treatment of mild cognitive impairment: a 6-month double-blind pilot clinical trial. Neurology. 2012 Jan 10;78(2):91–101. doi: 10.1212/WNL.0b013e31823efcbb. PMID: 22232050.22232050
2 Forlenza OV, Diniz BS, Radanovic M, . Disease-modifying properties of long-term lithium treatment for amnestic mild cognitive impairment: randomised controlled trial. Br J Psychiatry. 2011 May;198(5):351–6. doi: 10.1192/bjp.bp.110.080044. PMID: 21525519.21525519
3 Hars M, Herrmann FR, Gold G, . Effect of music-based multitask training on cognition and mood in older adults. Age Ageing. 2014 Mar;43(2):196–200. doi: 10.1093/ageing/aft163. PMID: 24212920.24212920
4 Bugos JA, Perlstein WM, McCrae CS, . Individualized piano instruction enhances executive functioning and working memory in older adults. Aging Ment Health. 2007 Jul;11(4):464–71. doi: 10.1080/13607860601086504. PMID: 17612811.17612811
5 Lucassen EA, Piaggi P, Dsurney J, . Sleep extension improves neurocognitive functions in chronically sleep-deprived obese individuals. PLoS One. 2014;9(1):e84832. doi: 10.1371/journal.pone.0084832. PMID: 24482677.24482677
6 Sun J, Kang J, Wang P, . Self-relaxation training can improve sleep quality and cognitive functions in the older: a one-year randomised controlled trial. J Clin Nurs. 2013 May;22(9–10):1270–80. doi: 10.1111/jocn.12096. PMID: 23574290.23574290
7 Lam LC, Chan WC, Leung T, . Would older adults with mild cognitive impairment adhere to and benefit from a structured lifestyle activity intervention to enhance cognition?: a cluster randomized controlled trial. PLoS One. 2015 31 Mar;10(3):e0118173. 10.1371/journal.pone.0118173. PMID: 25826620.25826620
8 Mortimer JA, Ding D, Borenstein AR, . Changes in brain volume and cognition in a randomized trial of exercise and social interaction in a community-based sample of non-demented Chinese elders. J Alzheimers Dis. 2012;30(4):757–66. doi: 10.3233/JAD-2012-120079. PMID: 22451320.22451320