# Appendix Q Diabetic Medication Treatment

Appendix Table Q1 Characteristics of eligible studies: diabetic medication treatments in adults with normal cognition

Appendix Table Q2 Summary risk of bias assessments: diabetic medication treatment in adults with normal cognition

Appendix Table Q3 Strength of evidence assessments: diabetic medication treatments versus standard of care/standard glycemic control in adults with normal cognition

Appendix Table Q4 Characteristics of eligible studies: diabetic medication treatments in adults with MCI

Appendix Table Q5 Summary risk of bias assessments: diabetic medication treatment in adults with MCI

## References for Appendix Q

1 Cukierman-Yaffe T, Bosch J, Diaz R, . Effects of basal insulin glargine and omega-3 fatty acid on cognitive decline and probable cognitive impairment in people with dysglycaemia: a substudy of the ORIGIN trial. Lancet Diabetes Endocrinol. 2014 Jul;2(7):562–72. doi: 10.1016/S2213-8587(14)70062-2. PMID: 24898834.24898834
2 Seaquist ER, Miller ME, Fonseca V, . Effect of thiazolidinediones and insulin on cognitive outcomes in ACCORD-MIND. J Diabetes Complications. 2013 Sep–Oct;27(5):485–91. 10.1016/j.jdiacomp.2013.03.005. PMID: 23680059.23680059
3 Launer LJ, Miller ME, Williamson JD, . Effects of intensive glucose lowering on brain structure and function in people with type 2 diabetes (ACCORD MIND): a randomised open-label substudy. Lancet Neurol. 2011 Nov;10(11):969–77. doi: 10.1016/S1474-4422(11)70188-0. PMID: 21958949.21958949
4 Cheatham RA, Roberts SB, Das SK, . Long-term effects of provided low and high glycemic load low energy diets on mood and cognition. Physiol Behav. 2009 Sep 7;98(3):374–9. doi: 10.1016/j.physbeh.2009.06.015. PMID: 19576915.19576915
5 Luchsinger JA, Palmas W, Teresi JA, . Improved diabetes control in the elderly delays global cognitive decline. J Nutr Health Aging. 2011 Jun;15(6):445–9. PMID: 21623465.21623465
6 Koekkoek PS, Ruis C, van den Donk M, . Intensive multifactorial treatment and cognitive functioning in screen-detected type 2 diabetes--the ADDITION-Netherlands study: a cluster-randomized trial. J Neurol Sci. 2012 Mar 15;314(1–2):71–7. doi: 10.1016/j.jns.2011.10.028. PMID: 22093142.22093142
7 Hildreth KL, Van Pelt RE, Moreau KL, . Effects of pioglitazone or exercise in older adults with mild cognitive impairment and insulin resistance: a pilot study. Dement Geriatr Cogn Dis Extra. 2015 Jan–Apr;5(1):51–63. 10.1159/000371509. PMID: 25852732.25852732
8 Luchsinger JA, Perez T, Chang H, . Metformin in amnestic mild cognitive impairment: Results of a pilot randomized placebo controlled clinical trial. Journal of Alzheimer’s Disease. 2016 15 Mar;51(2):501–14. doi: http://dx.doi.org/10.3233/JAD-150493. PMID: 609260209.