# Appendix P Antidementia Drugs

Appendix Table P1 Characteristics of eligible studies: antidementia interventions in adults with normal cognition

Appendix Table P2 Summary risk of bias assessments: antidementia drug interventions in adults with normal cognition

Appendix Table P3 Characteristics of eligible studies: antidementia interventions in adults with MCI

Appendix Table P4 Summary risk of bias assessments: antidementia drug interventions in adults with MCI

Appendix Table P5 Strength of evidence assessments: antidementia medication versus placebo control in adults with MCI

## References for Appendix P

1 Gavrilova SI, Kolykhalov IV, Fedorova YB, . Potential of Preventive Treatment of Alzheimer’s Disease: Results of a Three-Year Prospective Open Comparative Trial of the Efficacy and Safety of Courses of Treatment with Cerebrolysin and Cavinton in Elderly Patients with Mild Cognitive Impairment Syndrome. Neuroscience and Behavioral Physiology. 2011 May;41(4):391–8. doi: 10.1007/s11055-011-9427-4. PMID: 2011362050.
2 Devi G, Massimi S, Schultz S, . A double-blind, placebo-controlled trial of donepezil for the treatment of menopause-related cognitive loss. Gend Med. 2007 Dec;4(4):352–8. PMID: 18215726.18215726
3 Doody RS, Ferris SH, Salloway S, . Donepezil treatment of patients with MCI: a 48-week randomized, placebo-controlled trial. Neurology. 2009 May 5;72(18):1555–61. doi: 10.1212/01.wnl.0000344650.95823.03. PMID: 19176895.19176895
4 Schuff N, Suhy J, Goldman R, . An MRI substudy of a donepezil clinical trial in mild cognitive impairment. Neurobiol Aging. 2011 Dec;32(12):2318 e31–41. doi: 10.1016/j.neurobiolaging.2010.04.005. PMID: 20541841.20541841
5 Petrella JR, Prince SE, Krishnan S, . Effects of donepezil on cortical activation in mild cognitive impairment: a pilot double-blind placebo-controlled trial using functional MR imaging. AJNR Am J Neuroradiol. 2009 Feb;30(2):411–6. doi: 10.3174/ajnr.A1359. PMID: 19001543.19001543
6 Petersen RC, Thomas RG, Grundman M, . Vitamin E and donepezil for the treatment of mild cognitive impairment. N Engl J Med. 2005 Jun 9;352(23):2379–88. doi: 10.1056/NEJMoa050151. PMID: 15829527.15829527
7 Jack CR, Jr., Petersen RC, Grundman M, . Longitudinal MRI findings from the vitamin E and donepezil treatment study for MCI. Neurobiology of Aging. 2008 Sep;29(9):1285–95. PMID: 17452062.17452062
8 Salloway S, Ferris S, Kluger A, . Efficacy of donepezil in mild cognitive impairment: a randomized placebo-controlled trial. Neurology. 2004 Aug 24;63(4):651–7. PMID: 15326237.15326237
9 Reynolds CF, 3rd, Butters MA, Lopez O, . Maintenance treatment of depression in old age: a randomized, double-blind, placebo-controlled evaluation of the efficacy and safety of donepezil combined with antidepressant pharmacotherapy. Arch Gen Psychiatry. 2011 Jan;68(1):51–60. doi: 10.1001/archgenpsychiatry.2010.184. PMID: 21199965.21199965
10 Feldman HH, Ferris S, Winblad B, . Effect of rivastigmine on delay to diagnosis of Alzheimer’s disease from mild cognitive impairment: the InDDEx study. Lancet Neurol. 2007 Jun;6(6):501–12. doi: 10.1016/S1474-4422(07)70109-6. PMID: 17509485.17509485
11 Peters O, Lorenz D, Fesche A, . A combination of galantamine and memantine modifies cognitive function in subjects with amnestic MCI. J Nutr Health Aging. 2012;16(6):544–8. PMID: 22659994.22659994
12 Winblad B, Gauthier S, Scinto L, . Safety and efficacy of galantamine in subjects with mild cognitive impairment. Neurology. 2008 May 27;70(22):2024–35. doi: 10.1212/01.wnl.0000303815.69777.26. PMID: 18322263.18322263
13 Prins ND, van der Flier WA, Knol DL, . The effect of galantamine on brain atrophy rate in subjects with mild cognitive impairment is modified by apolipoprotein E genotype: post-hoc analysis of data from a randomized controlled trial. Alzheimers Res Ther 2014 21 Jul;6(4):47. 10.1186/alzrt275. PMID: 25478019.25478019