# Appendix O Nonsteroidal Anti-Inflammatory Drugs

Appendix Table O1 Characteristics of eligible studies: NSAIDs in adults with normal cognition

Appendix Table O2 Summary risk of bias assessments: NSAIDs in adults with normal cognition

Appendix Table O3 Strength of evidence assessments: NSAIDs in adults with normal cognition

Appendix Table O4 Characteristics of eligible studies: NSAIDs in adults with MCI

Appendix Table O5 Summary risk of bias assessments: NSAIDs in adults with MCI

## References for Appendix O

1 Adapt Research Group. Results of a follow-up study to the randomized Alzheimer’s Disease Anti-inflammatory Prevention Trial (ADAPT). Alzheimer’s & Dementia. 2013 Nov;9(6):714–23. doi: http://dx.doi.org/10.1016/j.jalz.2012.11.012. PMID: 23562431.23562431
2 Adapt Research Group, Lyketsos CG, Breitner JC, . Naproxen and celecoxib do not prevent AD in early results from a randomized controlled trial. Neurology. 2007 May 22;68(21):1800–8. PMID: 17460158.17460158
3 Adapt Research Group, Martin BK, Szekely C, . Cognitive function over time in the Alzheimer’s Disease Anti-inflammatory Prevention Trial (ADAPT): results of a randomized, controlled trial of naproxen and celecoxib. Archives of Neurology. 2008 Jul;65(7):896–905. doi: http://dx.doi.org/10.1001/archneur.2008.65.7.nct70006. PMID: 18474729.18474729
4 Breitner J, Baker L, Drye L, . Follow-up evaluation of cognitive function in the randomized Alzheimer’s disease anti-inflammatory prevention trial and its follow-up study. Alzheimer’s and Dementia. 2015;11(2):216–25.e1. doi: http://dx.doi.org/10.1016/j.jalz.2014.03.009. PMID: 53231681.
5 Breitner JC, Baker LD, Montine TJ, . Extended results of the Alzheimer’s disease anti-inflammatory prevention trial. Alzheimer’s & Dementia. 2011 Jul;7(4):402–11. doi: http://dx.doi.org/10.1016/j.jalz.2010.12.014. PMID: 21784351.21784351
6 Small GW, Siddarth P, Silverman DH, . Cognitive and cerebral metabolic effects of celecoxib versus placebo in people with age-related memory loss: randomized controlled study. American Journal of Geriatric Psychiatry. 2008 Dec;16(12):999–1009. doi: http://dx.doi.org/10.1097/JGP.0b013e31818cd3a4. PMID: 19038899.19038899
7 Kang JH, Cook N, Manson J, . Low dose aspirin and cognitive function in the women’s health study cognitive cohort. BMJ. 2007 May 12;334(7601):987. PMID: 17468120.17468120
8 Thal LJ, Ferris SH, Kirby L, . A randomized, double-blind, study of rofecoxib in patients with mild cognitive impairment. Neuropsychopharmacology. 2005 Jun;30(6):1204–15. PMID: 15742005.15742005