# Appendix N Lipid Lowering Treatment

Appendix Table N1 Characteristics of eligible studies: lipid lowering interventions in adults with normal cognition

Appendix Table N2 Summary risk of bias assessments: lipid lowering treatment in adults with normal cognition

Appendix Table N3 Strength of evidence assessments: lipid lowering interventions in adults with normal cognition

## References for Appendix N

1 Shepherd J, Blauw GJ, Murphy MB, . Pravastatin in elderly individuals at risk of vascular disease (PROSPER): a randomised controlled trial. Lancet. 2002 Nov 23;360(9346):1623–30. PMID: 12457784.12457784
2 Trompet S, van Vliet P, de Craen AJ, . Pravastatin and cognitive function in the elderly. Results of the PROSPER study. J Neurol. 2010 Jan;257(1):85–90. doi: 10.1007/s00415-009-5271-7. PMID: 19653027.19653027
3 Parale GP, Baheti NN, Kulkarni PM, . Effects of atorvastatin on higher functions. Eur J Clin Pharmacol. 2006 Apr;62(4):259–65. doi: 10.1007/s00228-005-0073-z. PMID: 16489473.16489473
4 Muldoon MF, Ryan CM, Sereika SM, . Randomized trial of the effects of simvastatin on cognitive functioning in hypercholesterolemic adults. Am J Med. 2004 Dec 1;117(11):823–9. doi: 10.1016/j.amjmed.2004.07.041. PMID: 15589485.15589485
5 Heart Protection Study Collaborative G. MRC/BHF Heart Protection Study of cholesterol lowering with simvastatin in 20,536 high-risk individuals: a randomised placebo-controlled trial. Lancet. 2002 Jul 6;360(9326):7–22. doi: 10.1016/S0140-6736(02)09327-3. PMID: 12114036.12114036
6 Muldoon MF, Barger SD, Ryan CM, . Effects of lovastatin on cognitive function and psychological well-being. Am J Med. 2000 May;108(7):538–46. PMID: 10806282.10806282
7 Santanello NC, Barber BL, Applegate WB, . Effect of pharmacologic lipid lowering on health-related quality of life in older persons: results from the Cholesterol Reduction in Seniors Program (CRISP) Pilot Study. J Am Geriatr Soc. 1997 Jan;45(1):8–14. PMID: 8994481.8994481
8 Tendolkar I, Enajat M, Zwiers MP, . One-year cholesterol lowering treatment reduces medial temporal lobe atrophy and memory decline in stroke-free elderly with atrial fibrillation: evidence from a parallel group randomized trial. Int J Geriatr Psychiatry. 2012 Jan;27(1):49–58. doi: 10.1002/gps.2688. PMID: 21308791.21308791
9 Williamson JD, Launer LJ, Bryan RN, . Cognitive function and brain structure in persons with type 2 diabetes mellitus after intensive lowering of blood pressure and lipid levels: a randomized clinical trial. JAMA Intern Med. 2014 Mar;174(3):324–33. doi: 10.1001/jamainternmed.2013.13656. PMID: 24493100.24493100
10 Carlsson CM, Papcke-Benson K, Carnes M, . Health-related quality of life and long-term therapy with pravastatin and tocopherol (vitamin E) in older adults. Drugs Aging. 2002;19(10):793–805. PMID: 12390056.12390056