# Appendix M Antihypertension Treatment

Appendix Table M1 Characteristics of eligible studies: antihypertension interventions in adults with normal cognition

Appendix Table M2 Summary risk of bias assessments: antihypertensives in adults with normal cognition

Appendix Table M3 Strength of evidence assessments: antihypertensives in adults with normal cognition

Appendix Table M4 Characteristics of eligible studies: antihypertension interventions in adults with MCI

Appendix Table M5 Summary risk of bias assessments: antihypertension in adults with mild cognitive impairment

## References for Appendix M

1 Peters R, Beckett N, Forette F, . Incident dementia and blood pressure lowering in the Hypertension in the Very Elderly Trial cognitive function assessment (HYVET-COG): a double-blind, placebo controlled trial. Lancet Neurology. 2008 Aug;7(8):683–9. doi: http://dx.doi.org/10.1016/S1474-4422(08)70143-1. PMID: 18614402.18614402
2 Patel A, Group AC, MacMahon S, . Effects of a fixed combination of perindopril and indapamide on macrovascular and microvascular outcomes in patients with type 2 diabetes mellitus (the ADVANCE trial): a randomised controlled trial. Lancet. 2007 Sep 8;370(9590):829–40. PMID: 17765963.17765963
3 Anderson C, Teo K, Gao P, . Renin-angiotensin system blockade and cognitive function in patients at high risk of cardiovascular disease: analysis of data from the ONTARGET and TRANSCEND studies. Lancet Neurology. 2011 Jan;10(1):43–53. doi: http://dx.doi.org/10.1016/S1474-4422(10)70250-7. PMID: 20980201.20980201
4 Saxby BK, Harrington F, Wesnes KA, . Candesartan and cognitive decline in older patients with hypertension: a substudy of the SCOPE trial. Neurology. 2008 May 6;70(19 Pt 2):1858–66. doi: http://dx.doi.org/10.1212/01.wnl.0000311447.85948.78. PMID: 18458219.18458219
5 Lithell H, Hansson L, Skoog I, . The Study on Cognition and Prognosis in the Elderly (SCOPE): principal results of a randomized double-blind intervention trial. Journal of Hypertension. 2003 May;21(5):875–86. PMID: 12714861.12714861
6 Skoog I, Lithell H, Hansson L, . Effect of baseline cognitive function and antihypertensive treatment on cognitive and cardiovascular outcomes: Study on COgnition and Prognosis in the Elderly (SCOPE). American Journal of Hypertension. 2005 Aug;18(8):1052–9. PMID: 16109319.16109319
7 Perez-Stable EJ, Halliday R, Gardiner PS, . The effects of propranolol on cognitive function and quality of life: a randomized trial among patients with diastolic hypertension. American Journal of Medicine. 2000 Apr 1;108(5):359–65. PMID: 10759091.10759091
8 Bird AS, Blizard RA, Mann AH. Treating hypertension in the older person: an evaluation of the association of blood pressure level and its reduction with cognitive performance. Journal of Hypertension. 1990 Feb;8(2):147–52. PMID: 2162877.2162877
9 Prince MJ, Bird AS, Blizard RA, . Is the cognitive function of older patients affected by antihypertensive treatment? Results from 54 months of the Medical Research Council’s trial of hypertension in older adults. BMJ. 1996 Mar 30;312(7034):801–5. PMID: 8608285.8608285
10 Forette F, Seux ML, Staessen JA, . The prevention of dementia with antihypertensive treatment: new evidence from the Systolic Hypertension in Europe (Syst-Eur) study.[Erratum appears in Arch Intern Med. 2003 Jan 27;163(2):241.]. Archives of Internal Medicine. 2002 Oct 14;162(18):2046–52. PMID: 12374512.12374512
11 Forette F, Seux ML, Staessen JA, . Prevention of dementia in randomised double-blind placebo-controlled Systolic Hypertension in Europe (Syst-Eur) trial. Lancet. 1998 Oct 24;352(9137):1347–51. PMID: 9802273.9802273
12 Applegate WB, Pressel S, Wittes J, . Impact of the treatment of isolated systolic hypertension on behavioral variables. Results from the systolic hypertension in the elderly program. Archives of Internal Medicine. 1994 Oct 10;154(19):2154–60. PMID: 7944835.7944835
13 SHEP Cooperative Research Group. Prevention of stroke by antihypertensive drug treatment in older persons with isolated systolic hypertension. Final results of the Systolic Hypertension in the Elderly Program (SHEP). SHEP Cooperative Research Group. JAMA. 1991 Jun 26;265(24):3255–64. PMID: 2046107.2046107
14 Gurland BJ, Teresi J, Smith WM, . Effects of treatment for isolated systolic hypertension on cognitive status and depression in the elderly. Journal of the American Geriatrics Society. 1988 Nov;36(11):1015–22. PMID: 3171039.3171039
15 Hajjar I, Hart M, Chen YL, . Antihypertensive therapy and cerebral hemodynamics in executive mild cognitive impairment: results of a pilot randomized clinical trial. Journal of the American Geriatrics Society. 2013 Feb;61(2):194–201. doi: http://dx.doi.org/10.1111/jgs.12100. PMID: 23350899.23350899
16 Fogari R, Mugellini A, Zoppi A, . Effect of telmisartan/hydrochlorothiazide vs lisinopril/hydrochlorothiazide combination on ambulatory blood pressure and cognitive function in elderly hypertensive patients. Journal of Human Hypertension. 2006 Mar;20(3):177–85. PMID: 16306998.16306998
17 Tedesco MA, Ratti G, Mennella S, . Comparison of losartan and hydrochlorothiazide on cognitive function and quality of life in hypertensive patients. American Journal of Hypertension. 1999 Nov;12(11 Pt 1):1130–4. PMID: 10604491.10604491
18 Williamson JD, Launer LJ, Bryan RN, . Cognitive function and brain structure in persons with type 2 diabetes mellitus after intensive lowering of blood pressure and lipid levels: a randomized clinical trial. JAMA Intern Med. 2014 Mar;174(3):324–33. doi: 10.1001/jamainternmed.2013.13656. PMID: 24493100.24493100
19 Sato N, Saijo Y, Sasagawa Y, . Combination of antihypertensive therapy in the elderly, multicenter investigation (CAMUI) trial: results after 1 year. J Hypertens. 2013 Jun;31(6):1245–55. doi: 10.1097/HJH.0b013e32835fdf60. PMID: 23492647.23492647
20 Fogari R, Mugellini A, Zoppi A, . Influence of losartan and atenolol on memory function in very elderly hypertensive patients. Journal of Human Hypertension. 2003 Nov;17(11):781–5. PMID: 14578918.14578918
21 Yodfat Y, Bar-On D, Amir M, . Quality of life in normotensives compared to hypertensive men treated with isradipine or methyldopa as monotherapy or in combination with captopril: the LOMIR-MCT-IL study. Journal of Human Hypertension. 1996 Feb;10(2):117–22. PMID: 8867566.8867566
22 Goldstein G, Materson BJ, Cushman WC, . Treatment of hypertension in the elderly: II. Cognitive and behavioral function. Results of a Department of Veterans Affairs Cooperative Study. Hypertension. 1990 Apr;15(4):361–9. PMID: 2318518.2318518
23 Starr JM, Whalley LJ, Deary IJ. The effects of antihypertensive treatment on cognitive function: results from the HOPE study. Journal of the American Geriatrics Society. 1996 Apr;44(4):411–5. PMID: 8636587.8636587
24 Starr JM, Whalley LJ. Differential cognitive outcomes in the Hypertensive Old People in Edinburgh study. Journal of the Neurological Sciences. 2005 Mar 15;229–230:103–7. PMID: 15760627.15760627