# Appendix L Vitamin Interventions

Appendix Table L1 Characteristics of eligible studies: vitamins in adults with normal cognition

Appendix Table L2 Characteristics eligible studies: B vitamin combinations vs. active control in adults with normal cognition

Appendix Table L3 Summary risk of bias assessments: vitamins in adults with normal cognition

Appendix Table L4 Strength of evidence assessments: vitamins in adults with normal cognition

Appendix Table L5 Characteristics of eligible studies: vitamins vs. inactive control in adults with MCI

Appendix Table L6 Summary risk of bias assessments: vitamins in adults with MCI

Appendix Table L7 Strength of evidence assessments: vitamins vs. inactive control in adults with MCI

## References for Appendix L

1 Chew EY, Clemons TE, Agron E, . Effect of Omega-3 Fatty Acids, Lutein/Zeaxanthin, or Other Nutrient Supplementation on Cognitive Function: The AREDS2 Randomized Clinical Trial. JAMA. 2015 Aug 25;314(8):791–801. doi: 10.1001/jama.2015.9677. PMID: 26305649.26305649
2 Grodstein F, O’Brien J, Kang JH, . Long-term multivitamin supplementation and cognitive function in men: a randomized trial. Ann Intern Med. 2013 Dec 17;159(12):806–14. doi: 10.7326/0003-4819-159-12-201312170-00006. PMID: 24490265.24490265
3 Kesse-Guyot E, Fezeu L, Jeandel C, . French adults’ cognitive performance after daily supplementation with antioxidant vitamins and minerals at nutritional doses: a post hoc analysis of the Supplementation in Vitamins and Mineral Antioxidants (SU.VI.MAX) trial. Am J Clin Nutr. 2011 Sep;94(3):892–9. doi: 10.3945/ajcn.110.007815. PMID: 21775560.21775560
4 McNeill G, Avenell A, Campbell MK, . Effect of multivitamin and multimineral supplementation on cognitive function in men and women aged 65 years and over: a randomised controlled trial. Nutr J. 2007;6:10. doi: 10.1186/1475-2891-6-10. PMID: 17474991.17474991
5 Wolters M, Hickstein M, Flintermann A, . Cognitive performance in relation to vitamin status in healthy elderly German women-the effect of 6-month multivitamin supplementation. Prev Med. 2005 Jul;41(1):253–9. doi: 10.1016/j.ypmed.2004.11.007. PMID: 15917019.15917019
6 Yaffe K, Clemons TE, McBee WL, . Impact of antioxidants, zinc, and copper on cognition in the elderly: a randomized, controlled trial. Neurology. 2004 Nov 9;63(9):1705–7. PMID: 15534261.15534261
7 Heart Protection Study Collaborative G. MRC/BHF Heart Protection Study of antioxidant vitamin supplementation in 20,536 high-risk individuals: a randomised placebo-controlled trial. Lancet. 2002 Jul 6;360(9326):23–33. doi: 10.1016/S0140-6736(02)09328-5. PMID: 12114037.12114037
8 Cockle S, Haller J, Kimber S, . The influence of multivitamins on cognitive function and mood in the elderly. Aging & Mental Health. 2000;4(4):339–53.
9 Smith A, Clark R, Nutt D, . Anti-oxidant vitamins and mental performance of the elderly. Human Psychopharmacology-Clinical and Experimental. 1999 Oct;14(7):459–71. doi: Doi 10.1002/(Sici)1099–1077(199910)14:7<459::Aid-Hup128>3.0.Co;2-0. PMID: WOS:000083485200003.
10 Durga J, van Boxtel MP, Schouten EG, . Effect of 3-year folic acid supplementation on cognitive function in older adults in the FACIT trial: a randomised, double blind, controlled trial. Lancet. 2007 Jan 20;369(9557):208–16. PMID: 17240287.17240287
11 van der Zwaluw NL, Dhonukshe-Rutten RA, van Wijngaarden JP, . Results of 2-year vitamin B treatment on cognitive performance: secondary data from an RCT. Neurology. 2014 Dec 2;83(23):2158–66. doi: 10.1212/WNL.0000000000001050. PMID: 25391305.25391305
12 Walker JG, Batterham PJ, Mackinnon AJ, . Oral folic acid and vitamin B-12 supplementation to prevent cognitive decline in community-dwelling older adults with depressive symptoms--the Beyond Ageing Project: a randomized controlled trial. Am J Clin Nutr. 2012 Jan;95(1):194–203. doi: 10.3945/ajcn.110.007799. PMID: 22170358.22170358
13 Andreeva VA, Kesse-Guyot E, Barberger-Gateau P, . Cognitive function after supplementation with B vitamins and long-chain omega-3 fatty acids: ancillary findings from the SU.FOL.OM3 randomized trial. Am J Clin Nutr. 2011 Jul;94(1):278–86. doi: 10.3945/ajcn.110.006320. PMID: 21593490.21593490
14 Brady CB, Gaziano JM, Cxypoliski RA, . Homocysteine lowering and cognition in CKD: the Veterans Affairs homocysteine study. Am J Kidney Dis. 2009 Sep;54(3):440–9. doi: 10.1053/j.ajkd.2009.05.013. PMID: 19628319.19628319
15 Kang JH, Cook N, Manson J, . A trial of B vitamins and cognitive function among women at high risk of cardiovascular disease. American Journal of Clinical Nutrition. 2008 Dec;88(6):1602–10. doi: http://dx.doi.org/10.3945/ajcn.2008.26404. PMID: 19064521.19064521
16 McMahon JA, Green TJ, Skeaff CM, . A controlled trial of homocysteine lowering and cognitive performance. N Engl J Med. 2006 Jun 29;354(26):2764–72. doi: 10.1056/NEJMoa054025. PMID: 16807413.16807413
17 Kang JH, Cook NR, Manson JE, . Vitamin E, vitamin C, beta carotene, and cognitive function among women with or at risk of cardiovascular disease: The Women’s Antioxidant and Cardiovascular Study. Circulation. 2009 Jun 2;119(21):2772–80. doi: 10.1161/CIRCULATIONAHA.108.816900. PMID: 19451353.19451353
18 Kang JH, Cook N, Manson J, . A randomized trial of vitamin E supplementation and cognitive function in women. Arch Intern Med. 2006 Dec 11–25;166(22):2462–8. 10.1001/archinte.166.22.2462. PMID: 17159011.17159011
19 Rossom RC, Espeland MA, Manson JE, . Calcium and vitamin D supplementation and cognitive impairment in the women’s health initiative. J Am Geriatr Soc. 2012 Dec;60(12):2197–205. doi: 10.1111/jgs.12032. PMID: 23176129.23176129
20 Stott DJ, MacIntosh G, Lowe GD, . Randomized controlled trial of homocysteine-lowering vitamin treatment in elderly patients with vascular disease. American Journal of Clinical Nutrition. 2005 Dec;82(6):1320–6. PMID: 16332666.16332666
21 Carlsson CM, Papcke-Benson K, Carnes M, . Health-related quality of life and long-term therapy with pravastatin and tocopherol (vitamin E) in older adults. Drugs Aging. 2002;19(10):793–805. PMID: 12390056.12390056
22 Naeini AM, Elmadfa I, Djazayery A, . The effect of antioxidant vitamins E and C on cognitive performance of the elderly with mild cognitive impairment in Isfahan, Iran: a double-blind, randomized, placebo-controlled trial. Eur J Nutr. 2014 Aug;53(5):1255–62. doi: 10.1007/s00394-013-0628-1. PMID: 24326981.24326981
23 Remington R, Lortie JJ, Hoffmann H, . A Nutritional Formulation for Cognitive Performance in Mild Cognitive Impairment: A Placebo-Controlled Trial with an Open-Label Extension. J Alzheimers Dis. 2015 01 Oct;48(3):591–5. 10.3233/JAD-150057. PMID: 26402075.26402075
24 Smith AD, Smith SM, de Jager CA, . Homocysteine-lowering by B vitamins slows the rate of accelerated brain atrophy in mild cognitive impairment: a randomized controlled trial. PLoS One. 2010;5(9):e12244. doi: 10.1371/journal.pone.0012244. PMID: 20838622.20838622
25 de Jager CA, Oulhaj A, Jacoby R, . Cognitive and clinical outcomes of homocysteine-lowering B-vitamin treatment in mild cognitive impairment: a randomized controlled trial. Int J Geriatr Psychiatry. 2012 Jun;27(6):592–600. doi: 10.1002/gps.2758. PMID: 21780182.21780182
26 Douaud G, Refsum H, de Jager CA, . Preventing Alzheimer’s disease-related gray matter atrophy by B-vitamin treatment. Proc Natl Acad Sci U S A. 2013 Jun 4;110(23):9523–8.doi: 10.1073/pnas.1301816110. PMID: 23690582.23690582
27 Oulhaj A, Jerneren F, Refsum H, . Omega-3 fatty acid status enhances the prevention of cognitive decline by B Vitamins in mild cognitive impairment. Journal of Alzheimer’s Disease. 2015 10 Dec;50(2):547–57. doi: http://dx.doi.org/10.3233/JAD-150777. PMID: 608047606.
28 van Uffelen JG, Chinapaw MJ, van Mechelen W, . Walking or vitamin B for cognition in older adults with mild cognitive impairment? A randomised controlled trial. British Journal of Sports Medicine. 2008 May;42(5):344–51. doi: http://dx.doi.org/10.1136/bjsm.2007.044735. PMID: 18308888.18308888
29 Petersen RC, Thomas RG, Grundman M, . Vitamin E and donepezil for the treatment of mild cognitive impairment. N Engl J Med. 2005 Jun 9;352(23):2379–88. doi: 10.1056/NEJMoa050151. PMID: 15829527.15829527
30 Jack CR, Jr., Petersen RC, Grundman M, . Longitudinal MRI findings from the vitamin E and donepezil treatment study for MCI. Neurobiology of Aging. 2008 Sep;29(9):1285–95. PMID: 17452062.17452062