# Appendix K Hormone Interventions

Appendix Table K1 Characteristics of eligible studies: hormone interventions vs. inactive controls in adults with normal cognition

Appendix Table K2 Summary risk of bias assessments: hormone interventions vs. inactive controls in adults with normal cognition

Appendix Table K3 Characteristics of eligible studies: hormone interventions vs. active controls in adults with normal cognition

Appendix Table K4 Summary risk of bias assessments: hormone interventions vs. active controls in adults with normal cognition

Appendix Table K5 Strength of evidence assessments: hormone therapies in adults with normal cognition

Appendix Table K6 Characteristics of eligible studies: hormone interventions vs. inactive controls in adults with MCI

Appendix Table K7 Summary risk of bias assessments: hormone interventions vs. inactive controls in adults with MCI

## References for Appendix K

1 Henderson VW, St John JA, Hodis HN, . Cognitive effects of estradiol after menopause: A randomized trial of the timing hypothesis. Neurology. 2016 Aug 16;87(7):699–708. doi: 10.1212/wnl.0000000000002980. PMID: 27421538.27421538
2 Wroolie TE, Kenna HA, Williams KE, . Cognitive Effects of Hormone Therapy Continuation or Discontinuation in a Sample of Women at Risk for Alzheimer Disease. American Journal of Geriatric Psychiatry. 2015 01 Nov;23(11):1117–26. doi: http://dx.doi.org/10.1016/j.jagp.2015.05.009. PMID: 609354671.26209223
3 Rasgon NL, Geist CL, Kenna HA, . Prospective randomized trial to assess effects of continuing hormone therapy on cerebral function in postmenopausal women at risk for dementia. PLoS One. 2014;9(3):e89095. doi: 10.1371/journal.pone.0089095. PMID: 24622517.24622517
4 Espeland MA, Shumaker SA, Leng I, . Long-term effects on cognitive function of postmenopausal hormone therapy prescribed to women aged 50 to 55 years. JAMA Intern Med. 2013 Aug 12;173(15):1429–36. doi: 10.1001/jamainternmed.2013.7727. PMID: 23797469.23797469
5 Espeland MA, Brunner RL, Hogan PE, . Long-term effects of conjugated equine estrogen therapies on domain-specific cognitive function: results from the Women’s Health Initiative study of cognitive aging extension. J Am Geriatr Soc. 2010 Jul;58(7):1263–71. doi: 10.1111/j.1532-5415.2010.02953.x. PMID: 20649689.20649689
6 Coker LH, Hogan PE, Bryan NR, . Postmenopausal hormone therapy and subclinical cerebrovascular disease: the WHIMS-MRI Study. Neurology. 2009 Jan 13;72(2):125–34. doi: 10.1212/01.wnl.0000339036.88842.9e. PMID: 19139363.19139363
7 Resnick SM, Espeland MA, An Y, . Effects of conjugated equine estrogens on cognition and affect in postmenopausal women with prior hysterectomy. J Clin Endocrinol Metab. 2009 Nov;94(11):4152–61. doi: 10.1210/jc.2009-1340. PMID: 19850684.19850684
8 Resnick SM, Espeland MA, Jaramillo SA, . Postmenopausal hormone therapy and regional brain volumes: the WHIMS-MRI Study. Neurology. 2009 Jan 13;72(2):135–42. doi: 10.1212/01.wnl.0000339037.76336.cf. PMID: 19139364.19139364
9 Resnick SM, Maki PM, Rapp SR, . Effects of combination estrogen plus progestin hormone treatment on cognition and affect. J Clin Endocrinol Metab. 2006 May;91(5):1802–10. doi: 10.1210/jc.2005-2097. PMID: 16522699.16522699
10 Espeland MA, Rapp SR, Shumaker SA, . Conjugated equine estrogens and global cognitive function in postmenopausal women: Women’s Health Initiative Memory Study. JAMA. 2004 Jun 23;291(24):2959–68. doi: 10.1001/jama.291.24.2959. PMID: 15213207.15213207
11 Shumaker SA, Legault C, Kuller L, . Conjugated equine estrogens and incidence of probable dementia and mild cognitive impairment in postmenopausal women: Women’s Health Initiative Memory Study. JAMA. 2004 Jun 23;291(24):2947–58. doi: 10.1001/jama.291.24.2947. PMID: 15213206.15213206
12 Rapp SR, Espeland MA, Shumaker SA, . Effect of estrogen plus progestin on global cognitive function in postmenopausal women: the Women’s Health Initiative Memory Study: a randomized controlled trial. Jama. 2003 May 28;289(20):2663–72. doi: 10.1001/jama.289.20.2663. PMID: 12771113.12771113
13 Gorenstein C, Renno J, Jr., Vieira Filho AH, . Estrogen replacement therapy and cognitive functions in healthy postmenopausal women: a randomized trial. Arch Womens Ment Health. 2011 Oct;14(5):367–73. doi: 10.1007/s00737-011-0230-6. PMID: 21732218.21732218
14 Pefanco MA, Kenny AM, Kaplan RF, . The effect of 3-year treatment with 0.25 mg/day of micronized 17beta-estradiol on cognitive function in older postmenopausal women. J Am Geriatr Soc. 2007 Mar;55(3):426–31. doi: 10.1111/j.1532-5415.2007.01085.x. PMID: 17341247.17341247
15 Yaffe K, Vittinghoff E, Ensrud KE, . Effects of ultra-low-dose transdermal estradiol on cognition and health-related quality of life. Arch Neurol. 2006 Jul;63(7):945–50. doi: 10.1001/archneur.63.7.945. PMID: 16831962.16831962
16 Kantarci K, Lowe VJ, Lesnick TG, . Early postmenopausal transdermal 17beta-estradiol therapy and amyloid-beta deposition. Journal of Alzheimer’s Disease. 2016;53(2):547–56. doi: http://dx.doi.org/10.3233/JAD-160258. PMID: 2016-36847-015.
17 Gleason CE, Dowling NM, Wharton W, . Effects of Hormone Therapy on Cognition and Mood in Recently Postmenopausal Women: Findings from the Randomized, Controlled KEEPS-Cognitive and Affective Study. PLoS Med. 2015 Jun;12(6):e1001833; discussion e. doi: 10.1371/journal.pmed.1001833. PMID: 26035291.26035291
18 Shumaker SA, Legault C, Rapp SR, . Estrogen plus progestin and the incidence of dementia and mild cognitive impairment in postmenopausal women: the Women’s Health Initiative Memory Study: a randomized controlled trial. JAMA. 2003 May 28;289(20):2651–62. doi: 10.1001/jama.289.20.2651. PMID: 12771112.12771112
19 Davison SL, Bell RJ, Robinson PJ, . Continuous-combined oral estradiol/drospirenone has no detrimental effect on cognitive performance and improves estrogen deficiency symptoms in early postmenopausal women: a randomized placebo-controlled trial. Menopause. 2013 Oct;20(10):1020–6. doi: 10.1097/GME.0b013e318287474f. PMID: 23591255.23591255
20 Alhola P, Tuomisto H, Saarinen R, . Estrogen + progestin therapy and cognition: a randomized placebo-controlled double-blind study. J Obstet Gynaecol Res. 2010 Aug;36(4):796–802. doi: 10.1111/j.1447-0756.2010.01214.x. PMID: 20666948.20666948
21 Maki PM, Rubin LH, Fornelli D, . Effects of botanicals and combined hormone therapy on cognition in postmenopausal women. Menopause. 2009 Nov–Dec;16(6):1167–77. 10.1097/gme.0b013e3181ace484. PMID: 19590458.19590458
22 Tierney MC, Oh P, Moineddin R, . A randomized double-blind trial of the effects of hormone therapy on delayed verbal recall in older women. Psychoneuroendocrinology. 2009 Aug;34(7):1065–74. doi: 10.1016/j.psyneuen.2009.02.009. PMID: 19297102.19297102
23 Grady D, Yaffe K, Kristof M, . Effect of postmenopausal hormone therapy on cognitive function: the Heart and Estrogen/progestin Replacement Study. Am J Med. 2002 Nov;113(7):543–8. PMID: 12459399.12459399
24 Binder EF, Schechtman KB, Birge SJ, . Effects of hormone replacement therapy on cognitive performance in elderly women. Maturitas. 2001 Apr 20;38(2):137–46. PMID: 11306202.11306202
25 Kritz-Silverstein D, von Muhlen D, Laughlin GA, . Effects of dehydroepiandrosterone supplementation on cognitive function and quality of life: the DHEA and Well-Ness (DAWN) Trial. J Am Geriatr Soc. 2008 Jul;56(7):1292–8. doi: 10.1111/j.1532-5415.2008.01768.x. PMID: 18482290.18482290
26 Vaughan C, Goldstein FC, Tenover JL. Exogenous testosterone alone or with finasteride does not improve measurements of cognition in healthy older men with low serum testosterone. J Androl. 2007 Nov–Dec;28(6):875–82. 10.2164/jandrol.107.002931. PMID: 17609296.17609296
27 Kenny AM, Bellantonio S, Gruman CA, . Effects of transdermal testosterone on cognitive function and health perception in older men with low bioavailable testosterone levels. J Gerontol A Biol Sci Med Sci. 2002 May;57(5):M321–5. PMID: 11983727.11983727
28 Yaffe K, Krueger K, Cummings SR, . Effect of raloxifene on prevention of dementia and cognitive impairment in older women: the Multiple Outcomes of Raloxifene Evaluation (MORE) randomized trial. Am J Psychiatry. 2005 Apr;162(4):683–90. doi: 10.1176/appi.ajp.162.4.683. PMID: 15800139.15800139
29 Yaffe K, Krueger K, Sarkar S, . Cognitive function in postmenopausal women treated with raloxifene. N Engl J Med. 2001 Apr 19;344(16):1207–13. doi: 10.1056/nejm200104193441604. PMID: 11309635.11309635
30 Nickelsen T, Lufkin EG, Riggs BL, . Raloxifene hydrochloride, a selective estrogen receptor modulator: safety assessment of effects on cognitive function and mood in postmenopausal women. Psychoneuroendocrinology. 1999 Jan;24(1):115–28. PMID: 10098223.10098223
31 Henderson VW, St John JA, Hodis HN, . Long-term soy isoflavone supplementation and cognition in women: a randomized, controlled trial. Neurology. 2012 Jun 5;78(23):1841–8. doi: 10.1212/WNL.0b013e318258f822. PMID: 22665144.22665144
32 Gleason CE, Carlsson CM, Barnet JH, . A preliminary study of the safety, feasibility and cognitive efficacy of soy isoflavone supplements in older men and women. Age Ageing. 2009 Jan;38(1):86–93. doi: 10.1093/ageing/afn227. PMID: 19054783.19054783
33 Ho SC, Chan AS, Ho YP, . Effects of soy isoflavone supplementation on cognitive function in Chinese postmenopausal women: a double-blind, randomized, controlled trial. Menopause. 2007 May–Jun;14(3 Pt 1):489–99. 10.1097/GME.0b013e31802c4f4f. PMID: 17308499.17308499
34 Casini ML, Marelli G, Papaleo E, . Psychological assessment of the effects of treatment with phytoestrogens on postmenopausal women: a randomized, double-blind, crossover, placebo-controlled study. Fertil Steril. 2006 Apr;85(4):972–8. doi: 10.1016/j.fertnstert.2005.09.048. PMID: 16580383.16580383
35 Kreijkamp-Kaspers S, Kok L, Grobbee DE, . Effect of soy protein containing isoflavones on cognitive function, bone mineral density, and plasma lipids in postmenopausal women: a randomized controlled trial. Jama. 2004 Jul 7;292(1):65–74. doi: 10.1001/jama.292.1.65. PMID: 15238592.15238592
36 Kritz-Silverstein D, Von Muhlen D, Barrett-Connor E, . Isoflavones and cognitive function in older women: the SOy and Postmenopausal Health In Aging (SOPHIA) Study. Menopause. 2003 May–Jun;10(3):196–202. PMID: 12792289.12792289
37 Howes JB, Bray K, Lorenz L, . The effects of dietary supplementation with isoflavones from red clover on cognitive function in postmenopausal women. Climacteric. 2004 Mar;7(1):70–7. PMID: 15259285.15259285
38 Pan HA, Wang ST, Pai MC, . Cognitive function variations in postmenopausal women treated with continuous, combined HRT or tibolone. A comparison. J Reprod Med. 2003 May;48(5):375–80. PMID: 12815913.12815913
39 Moller MC, Radestad AF, von Schoultz B, . Effect of estrogen and testosterone replacement therapy on cognitive fatigue. Gynecol Endocrinol. 2013 Feb;29(2):173–6. doi: 10.3109/09513590.2012.730568. PMID: 23095007.23095007
40 Moller MC, Bartfai AB, Radestad AF. Effects of testosterone and estrogen replacement on memory function. Menopause. 2010 Sep–Oct;17(5):983–9. 10.1097/gme.0b013e3181dc2e40. PMID: 20555288.20555288
41 Legault C, Maki PM, Resnick SM, . Effects of tamoxifen and raloxifene on memory and other cognitive abilities: cognition in the study of tamoxifen and raloxifene. J Clin Oncol. 2009 Nov 1;27(31):5144–52. doi: 10.1200/JCO.2008.21.0716. PMID: 19770382.19770382
42 Espeland MA, Shumaker SA, Limacher M, . Relative effects of tamoxifen, raloxifene, and conjugated equine estrogens on cognition. J Womens Health (Larchmt). 2010 Mar;19(3):371–9. doi: 10.1089/jwh.2009.1605. PMID: 20136553.20136553
43 Cherrier MM, Anderson K, Shofer J, . Testosterone treatment of men with mild cognitive impairment and low testosterone levels. Am J Alzheimers Dis Other Demen. 2015 Jun;30(4):421–30. doi: 10.1177/1533317514556874. PMID: 25392187.25392187
44 Kato-Kataoka A, Sakai M, Ebina R, . Soybean-derived phosphatidylserine improves memory function of the elderly Japanese subjects with memory complaints. J Clin Biochem Nutr. 2010 Nov;47(3):246–55. doi: 10.3164/jcbn.10-62. PMID: 21103034.21103034