# Appendix J Multimodal Interventions

Appendix Table J1 Characteristics of eligible studies: multimodal interventions vs. inactive controls in adults with normal cognition

Appendix Table J2 Characteristics of eligible studies: multimodal interventions vs. active controls in adults with normal cognition

Appendix Table J3 Summary risk of bias assessments: multimodal interventions in adults with normal cognition

Appendix Table J4 Strength of evidence assessments: multimodal interventions versus inactive control in adults with normal cognition

Appendix Table J5 Strength of evidence assessments: multimodal interventions versus active comparison in adults with normal cognition

Appendix Table J6 Characteristics of eligible studies: multimodal interventions vs. inactive controls in adults with MCI

Appendix Table J7 Characteristics of eligible studies: multimodal interventions vs. active controls in adults with MCI

Appendix Table J8 Summary Risk of Bias Assessments: Multimodal interventions in adults with MCI

## References for Appendix J

1 Lehtisalo J, Lindstrom J, Ngandu T, . Association of Long-Term Dietary Fat Intake, Exercise, and Weight with Later Cognitive Function in the Finnish Diabetes Prevention Study. Journal of Nutrition, Health & Aging. 2016 Feb;20(2):146–54. doi: http://dx.doi.org/10.1007/s12603-015-0565-1. PMID: 26812510.26812510
2 Napoli N, Shah K, Waters DL, . Effect of weight loss, exercise, or both on cognition and quality of life in obese older adults. Am J Clin Nutr. 2014 Jul;100(1):189–98. doi: 10.3945/ajcn.113.082883. PMID: 24787497.24787497
3 Komulainen P, Kivipelto M, Lakka T, . Exercise, fitness and cognition–A randomised controlled trial in older individuals: The DR’s EXTRA study. European Geriatric Medicine. 2010;1(5):266–72.
4 Martin CK, Anton SD, Han H, . Examination of cognitive function during six months of calorie restriction: results of a randomized controlled trial. Rejuvenation Res. 2007 Jun;10(2):179–90. doi: 10.1089/rej.2006.0502. PMID: 17518698.17518698
5 Hars M, Herrmann FR, Gold G, . Effect of music-based multitask training on cognition and mood in older adults. Age Ageing. 2014 Mar;43(2):196–200. doi: 10.1093/ageing/aft163. PMID: 24212920.24212920
6 Tesky VA, Thiel C, Banzer W, . Effects of a Group Program to Increase Cognitive Performance Through Cognitively Stimulating Leisure Activities in Healthy Older Subjects. GeroPsych. 2011 01 Jun;24(2):83–92. 10.1024/1662-9647/a000035. PMID: 2011313185.
7 Oswald WD, Gunzelmann T, Rupprecht R, . Differential effects of single versus combined cognitive and physical training with older adults: the SimA study in a 5-year perspective. European Journal of Ageing. 2006;3(4):179–92.28794762
8 Carlson MC, Saczynski JS, Rebok GW, . Exploring the effects of an “everyday” activity program on executive function and memory in older adults: Experience Corps. Gerontologist. 2008 Dec;48(6):793–801. PMID: 19139252.19139252
9 Ngandu T, Lehtisalo J, Solomon A, . A 2 year multidomain intervention of diet, exercise, cognitive training, and vascular risk monitoring versus control to prevent cognitive decline in at-risk elderly people (FINGER): a randomised controlled trial. Lancet. 2015 Jun 6;385(9984):2255–63. doi: 10.1016/S0140-6736(15)60461-5. PMID: 25771249.25771249
10 van de Rest O, van der Zwaluw NL, Tieland M, . Effect of resistance-type exercise training with or without protein supplementation on cognitive functioning in frail and pre-frail elderly: secondary analysis of a randomized, double-blind, placebo-controlled trial. Mech Ageing Dev. 2014 Mar–Apr;136–137:85–93. 10.1016/j.mad.2013.12.005. PMID: 24374288.24374288
11 Clare L, Nelis SM, Jones IR, . The Agewell trial: a pilot randomised controlled trial of a behaviour change intervention to promote healthy ageing and reduce risk of dementia in later life. BMC Psychiatry. 2015;15:25. doi: 10.1186/s12888-015-0402-4. PMID: 25880911.25880911
12 Clark F, Jackson J, Carlson M, . Effectiveness of a lifestyle intervention in promoting the well-being of independently living older people: results of the Well Elderly 2 Randomised Controlled Trial. J Epidemiol Community Health. 2012 Sep;66(9):782–90. doi: 10.1136/jech.2009.099754. PMID: 21636614.21636614
13 Lee KS, Lee Y, Back JH, . Effects of a multidomain lifestyle modification on cognitive function in older adults: an eighteen-month community-based cluster randomized controlled trial. Psychother Psychosom. 2014;83(5):270–8. doi: 10.1159/000360820. PMID: 25116574.25116574
14 Yesavage JA, Friedman L, Ashford JW, . Acetylcholinesterase inhibitor in combination with cognitive training in older adults. J Gerontol B Psychol Sci Soc Sci. 2008 Sep;63(5):P288–94. PMID: 18818443.18818443
15 Moll van Charante EP, Richard E, Eurelings LS, . Effectiveness of a 6-year multidomain vascular care intervention to prevent dementia (preDIVA): A cluster-randomised controlled trial. The Lancet. 2016 Aug;388(10046):797–805. doi: http://dx.doi.org/10.1016/S0140-6736%2816%2930950-3.
16 Eggenberger P, Schumacher V, Angst M, . Does multicomponent physical exercise with simultaneous cognitive training boost cognitive performance in older adults? A 6-month randomized controlled trial with a 1-year follow-up. Clin Interv Aging. 2015 17 Aug;10:1335–49. 10.2147/CIA.S87732. PMID: 26316729.26316729
17 McDaniel MA, Binder EF, Bugg JM, . Effects of cognitive training with and without aerobic exercise on cognitively demanding everyday activities. Psychol Aging. 2014 Sep;29(3):717–30. doi: 10.1037/a0037363. PMID: 25244489.25244489
18 Fiatarone Singh MA, Gates N, Saigal N, . The Study of Mental and Resistance Training (SMART) study-resistance training and/or cognitive training in mild cognitive impairment: a randomized, double-blind, double-sham controlled trial. J Am Med Dir Assoc. 2014 Dec;15(12):873–80. doi: 10.1016/j.jamda.2014.09.010. PMID: 25444575.25444575
19 Johari SM, Shahar S, Ng TP, . A Preliminary Randomized Controlled Trial of Multifaceted Educational Intervention for Mild Cognitive Impairment Among Elderly Malays in Kuala Lumpur. International Journal of Gerontology. 2014 Jun;8(2):74–80. doi: 10.1016/j.ijge.2013.07.002. PMID: WOS:000339088200006.
20 Kobe T, Witte A, Schnelle A, . Combined omega-3 fatty acids, aerobic exercise and cognitive stimulation prevents decline in gray matter volume of the frontal, Parietal and cingulate cortex in patients with mild cognitive impairment. NeuroImage. 2016 01 May;131:226–38. doi: http://dx.doi.org/10.1016/j.neuroimage.2015.09.050. PMID: 607245692.26433119
21 Lam LC, Chan WC, Leung T, . Would older adults with mild cognitive impairment adhere to and benefit from a structured lifestyle activity intervention to enhance cognition?: a cluster randomized controlled trial. PLoS One. 2015 31 Mar;10(3):e0118173. 10.1371/journal.pone.0118173. PMID: 25826620.25826620