# Appendix I Diet Interventions

Appendix Table I1 Characteristics of eligible studies: nutrition/lifestyle interventions in adults with normal cognition

Appendix Table I2 Summary risk of bias assessments: diet interventions in adults with normal cognition

## References for Appendix I

1 Martin CK, Anton SD, Han H, . Examination of cognitive function during six months of calorie restriction: results of a randomized controlled trial. Rejuvenation Res. 2007 Jun;10(2):179–90. doi: 10.1089/rej.2006.0502. PMID: 17518698.17518698
2 Napoli N, Shah K, Waters DL, . Effect of weight loss, exercise, or both on cognition and quality of life in obese older adults. Am J Clin Nutr. 2014 Jul;100(1):189–98. doi: 10.3945/ajcn.113.082883. PMID: 24787497.24787497
3 Brinkworth GD, Buckley JD, Noakes M, . Long-term effects of a very low-carbohydrate diet and a low-fat diet on mood and cognitive function. Arch Intern Med. 2009 Nov 9;169(20):1873–80. doi: 10.1001/archinternmed.2009.329. PMID: 19901139.19901139
4 Valls-Pedret C, Sala-Vila A, Serra-Mir M, . Mediterranean Diet and Age-Related Cognitive Decline: A Randomized Clinical Trial. JAMA Intern Med. 2015 Jul;175(7):1094–103. doi: 10.1001/jamainternmed.2015.1668. PMID: 25961184.25961184
5 Martinez-Lapiscina EH, Clavero P, Toledo E, . Mediterranean diet improves cognition: the PREDIMED-NAVARRA randomised trial. J Neurol Neurosurg Psychiatry. 2013 Dec;84(12):1318–25. doi: 10.1136/jnnp-2012-304792. PMID: 23670794.23670794
6 Martinez-Lapiscina EH, Clavero P, Toledo E, . Virgin olive oil supplementation and long-term cognition: the PREDIMED-NAVARRA randomized, trial. J Nutr Health Aging. 2013;17(6):544–52. doi: 10.1007/s12603-013-0027-6. PMID: 23732551.23732551
7 Komulainen P, Kivipelto M, Lakka T, . Exercise, fitness and cognition–A randomised controlled trial in older individuals: The DR’s EXTRA study. European Geriatric Medicine. 2010;1(5):266–72.
8 van der Zwaluw NL, van de Rest O, Tieland M, . The impact of protein supplementation on cognitive performance in frail elderly. Eur J Nutr. 2014 Apr;53(3):803–12. doi: 10.1007/s00394-013-0584-9. PMID: 24045855.24045855
9 Wouters-Wesseling W, Wagenaar LW, Rozendaal M, . Effect of an enriched drink on cognitive function in frail elderly persons. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2005 Feb;60(2):265–70. PMID: 15814873.15814873