# Appendix H Nutraceutical Interventions

Appendix Table H1 Characteristics of eligible studies: nutraceutical interventions in adults with normal cognition

Table H2 Summary risk of bias assessments: nutraceuticals interventions in adults with normal cognition

Appendix Table H3 Strength of evidence assessments: nutraceutical interventions in adults with normal cognition

Appendix Table H4 Characteristics of eligible studies: Intervention type in adults with MCI

Appendix Table H5 Summary risk of bias assessments: nutraceuticals in adults with MCI

## References for Appendix H

1 Boespflug EL, McNamara RK, Eliassen JC, . Fish Oil Supplementation Increases Event-Related Posterior Cingulate Activation in Older Adults with Subjective Memory Impairment. J Nutr Health Aging. 2016 Feb;20(2):161–9. doi: 10.1007/s12603-015-0609-6. PMID: 26812512.26812512
2 Cukierman-Yaffe T, Bosch J, Diaz R, . Effects of basal insulin glargine and omega-3 fatty acid on cognitive decline and probable cognitive impairment in people with dysglycaemia: a substudy of the ORIGIN trial. The Lancet Diabetes & Endocrinology. 2014 Jul;2(7):562–72. doi: http://dx.doi.org/10.1016/S2213-8587(14)70062-2. PMID: 24898834.24898834
3 Mahmoudi MJ, Hedayat M, Sharifi F, . Effect of low dose omega-3 poly unsaturated fatty acids on cognitive status among older people: a double-blind randomized placebo-controlled study. J Diabetes Metab Disord. 2014 Feb 07;13(1):34. doi: 10.1186/2251-6581-13-34. PMID: 24507770.24507770
4 Witte AV, Kerti L, Hermannstadter HM, . Long-chain omega-3 fatty acids improve brain function and structure in older adults. Cerebral Cortex. 2014 Nov;24(11):3059–68. doi: http://dx.doi.org/10.1093/cercor/bht163. PMID: 23796946.23796946
5 Stonehouse W, Conlon CA, Podd J, . DHA supplementation improved both memory and reaction time in healthy young adults: a randomized controlled trial. American Journal of Clinical Nutrition. 2013 May;97(5):1134–43. doi: http://dx.doi.org/10.3945/ajcn.112.053371. PMID: 23515006.23515006
6 Geleijnse JM, Giltay EJ, Kromhout D. Effects of n-3 fatty acids on cognitive decline: a randomized, double-blind, placebo-controlled trial in stable myocardial infarction patients. Alzheimer’s & Dementia. 2012 Jul;8(4):278–87. doi: http://dx.doi.org/10.1016/j.jalz.2011.06.002. PMID: 21967845.21967845
7 Andreeva VA, Kesse-Guyot E, Barberger-Gateau P, . Cognitive function after supplementation with B vitamins and long-chain omega-3 fatty acids: ancillary findings from the SU.FOL.OM3 randomized trial. Am J Clin Nutr. 2011 Jul;94(1):278–86. doi: 10.3945/ajcn.110.006320. PMID: 21593490.21593490
8 Dangour AD, Allen E, Elbourne D, . Effect of 2-y n-3 long-chain polyunsaturated fatty acid supplementation on cognitive function in older people: a randomized, double-blind, controlled trial. American Journal of Clinical Nutrition. 2010 Jun;91(6):1725–32. doi: http://dx.doi.org/10.3945/ajcn.2009.29121. PMID: 20410089.20410089
9 Yurko-Mauro K, McCarthy D, Rom D, . Beneficial effects of docosahexaenoic acid on cognition in age-related cognitive decline. Alzheimer’s & Dementia. 2010 Nov;6(6):456–64. doi: http://dx.doi.org/10.1016/j.jalz.2010.01.013. PMID: 20434961.20434961
10 van de Rest O, Geleijnse JM, Kok FJ, . Effect of fish oil on cognitive performance in older subjects: a randomized, controlled trial. Neurology. 2008 Aug 5;71(6):430–8. doi: http://dx.doi.org/10.1212/01.wnl.0000324268.45138.86. PMID: 18678826.18678826
11 Lewis JE, Melillo AB, Tiozzo E, . A double-blind, randomized clinical trial of dietary supplementation on cognitive and immune functioning in healthy older adults.[Erratum appears in BMC Complement Altern Med. 2014;14:332]. BMC Complementary & Alternative Medicine. 2014;14:43. doi: http://dx.doi.org/10.1186/1472-6882-14-43. PMID: 24495355.24495355
12 Vellas B, Coley N, Ousset PJ, . Long-term use of standardised Ginkgo biloba extract for the prevention of Alzheimer’s disease (GuidAge): a randomised placebo-controlled trial. Lancet Neurology. 2012 Oct;11(10):851–9. doi: http://dx.doi.org/10.1016/S1474-4422(12)70206-5. PMID: 22959217.22959217
13 Snitz BE, O’Meara ES, Carlson MC, . Ginkgo biloba for preventing cognitive decline in older adults: a randomized trial. JAMA. 2009 Dec 23;302(24):2663–70. doi: http://dx.doi.org/10.1001/jama.2009.1913. PMID: 20040554.20040554
14 DeKosky ST, Williamson JD, Fitzpatrick AL, . Ginkgo biloba for prevention of dementia: a randomized controlled trial.[Erratum appears in JAMA. 2008 Dec 17;300(23):2730]. JAMA. 2008 Nov 19;300(19):2253–62. doi: http://dx.doi.org/10.1001/jama.2008.683. PMID: 19017911.19017911
15 Dodge HH, Zitzelberger T, Oken BS, . A randomized placebo-controlled trial of Ginkgo biloba for the prevention of cognitive decline. Neurology. 2008 May 6;70(19 Pt 2):1809–17. doi: http://dx.doi.org/10.1212/01.wnl.0000303814.13509.db. PMID: 18305231.18305231
16 Strike SC, Carlisle A, Gibson EL, . A High Omega-3 Fatty Acid Multinutrient Supplement Benefits Cognition and Mobility in Older Women: A Randomized, Double-blind, Placebo-controlled Pilot Study. J Gerontol A Biol Sci Med Sci. 2016 Feb;71(2):236–42. doi: 10.1093/gerona/glv109. PMID: 26265727.26265727
17 Witte AV, Kerti L, Margulies DS, . Effects of resveratrol on memory performance, hippocampal functional connectivity, and glucose metabolism in healthy older adults. Journal of Neuroscience. 2014 Jun 4;34(23):7862–70. doi: http://dx.doi.org/10.1523/JNEUROSCI.0385-14.2014. PMID: 24899709.24899709
18 Schiepers OJ, de Groot RH, van Boxtel MP, . Consuming functional foods enriched with plant sterol or stanol esters for 85 weeks does not affect neurocognitive functioning or mood in statin-treated hypercholesterolemic individuals. Journal of Nutrition. 2009 Jul;139(7):1368–73. doi: http://dx.doi.org/10.3945/jn.108.103721. PMID: 19458031.19458031
19 Chew EY, Clemons TE, Agron E, . Effect of Omega-3 Fatty Acids, Lutein/Zeaxanthin, or Other Nutrient Supplementation on Cognitive Function: The AREDS2 Randomized Clinical Trial. JAMA. 2015 Aug 25;314(8):791–801. doi: 10.1001/jama.2015.9677. PMID: 26305649.26305649
20 Bun S, Ikejima C, Kida J, . A combination of supplements may reduce the risk of Alzheimer’s disease in elderly Japanese with normal cognition. J Alzheimers Dis. 2015;45(1):15–25. doi: 10.3233/JAD-142232. PMID: 25524956.25524956
21 Lee LK, Shahar S, Chin AV, . Docosahexaenoic acid-concentrated fish oil supplementation in subjects with mild cognitive impairment (MCI): a 12-month randomised, double-blind, placebo-controlled trial. Psychopharmacology. 2013 Feb;225(3):605–12. doi: http://dx.doi.org/10.1007/s00213-012-2848-0. PMID: 22932777.22932777
22 Gavrilova SI, Preuss UW, Wong JW, . Efficacy and safety of Ginkgo biloba extract EGb 761 in mild cognitive impairment with neuropsychiatric symptoms: a randomized, placebo-controlled, double-blind, multi-center trial. International Journal of Geriatric Psychiatry. 2014 Oct;29(10):1087–95. doi: http://dx.doi.org/10.1002/gps.4103. PMID: 24633934.24633934
23 Sinn N, Milte CM, Street SJ, . Effects of n-3 fatty acids, EPA v. DHA, on depressive symptoms, quality of life, memory and executive function in older adults with mild cognitive impairment: a 6-month randomised controlled trial. British Journal of Nutrition. 2012 Jun;107(11):1682–93. doi: http://dx.doi.org/10.1017/S0007114511004788. PMID: 21929835.21929835