# Appendix G Physical Activity Interventions

Appendix Table G1 Characteristics of eligible studies: physical activity interventions vs. inactive controls in adults with normal cognition

Appendix Table G2 Characteristics of eligible studies: physical activity interventions vs. active controls in adults with normal cognition

Appendix Table G3 Summary risk of bias assessments: physical activity interventions in adults with normal cognition

Appendix Table G4 Strength of evidence assessments: physical activity interventions versus inactive control in adults with normal cognition

Appendix G Table 5 Characteristics of eligible studies: physical activity interventions vs. inactive controls in adults with MCI

Appendix Table G6 Characteristics of eligible studies: physical activity interventions vs. active controls in adults with MCI

Appendix Table G7 Summary risk of bias assessments: physical activity interventions in adults with MCI

Appendix Table G8 Strength of evidence assessments: physical activity interventions versus inactive control in adults with MCI

## References for Appendix G

1 Bun S, Ikejima C, Kida J, . A combination of supplements may reduce the risk of Alzheimer’s disease in elderly Japanese with normal cognition. J Alzheimers Dis. 2015;45(1):15–25. doi: 10.3233/JAD-142232. PMID: 25524956.25524956
2 Sink KM, Espeland MA, Castro CM, . Effect of a 24-Month Physical Activity Intervention vs Health Education on Cognitive Outcomes in Sedentary Older Adults: The LIFE Randomized Trial. JAMA. 2015 Aug 25;314(8):781–90. doi: 10.1001/jama.2015.9617. PMID: 26305648.26305648
3 Napoli N, Shah K, Waters DL, . Effect of weight loss, exercise, or both on cognition and quality of life in obese older adults. Am J Clin Nutr. 2014 Jul;100(1):189–98. doi: 10.3945/ajcn.113.082883. PMID: 24787497.24787497
4 Klusmann V, Evers A, Schwarzer R, . Complex mental and physical activity in older women and cognitive performance: a 6-month randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2010 Jun;65(6):680–8. doi: 10.1093/gerona/glq053. PMID: 20418350.20418350
5 Evers A, Klusmann V, Schwarzer R, . Improving cognition by adherence to physical or mental exercise: a moderated mediation analysis. Aging Ment Health. 2011 May;15(4):446–55. doi: 10.1080/13607863.2010.543657. PMID: 21500011.21500011
6 Rosano C, Venkatraman VK, Guralnik J, . Psychomotor speed and functional brain MRI 2 years after completing a physical activity treatment. J Gerontol A Biol Sci Med Sci. 2010 Jun;65(6):639–47. doi: 10.1093/gerona/glq038. PMID: 20348185.20348185
7 Taylor-Piliae RE, Newell KA, Cherin R, . Effects of Tai Chi and Western exercise on physical and cognitive functioning in healthy community-dwelling older adults. J Aging Phys Act. 2010 Jul;18(3):261–79. PMID: 20651414.20651414
8 Williamson JD, Espeland M, Kritchevsky SB, . Changes in cognitive function in a randomized trial of physical activity: results of the lifestyle interventions and independence for elders pilot study. J Gerontol A Biol Sci Med Sci. 2009 Jun;64(6):688–94. doi: 10.1093/gerona/glp014. PMID: 19244157.19244157
9 Liu-Ambrose T, Donaldson MG, Ahamed Y, . Otago home-based strength and balance retraining improves executive functioning in older fallers: a randomized controlled trial. Journal of the American Geriatrics Society. 2008 Oct;56(10):1821–30. doi: http://dx.doi.org/10.1111/j.1532-5415.2008.01931.x. PMID: 18795987.18795987
10 Oswald WD, Gunzelmann T, Rupprecht R, . Differential effects of single versus combined cognitive and physical training with older adults: the SimA study in a 5-year perspective. European Journal of Ageing. 2006;3(4):179–92.28794762
11 Williams P, Lord SR. Effects of group exercise on cognitive functioning and mood in older women. Australian & New Zealand Journal of Public Health. 1997 Feb;21(1):45–52. PMID: 9141729.9141729
12 van de Rest O, van der Zwaluw NL, Tieland M, . Effect of resistance-type exercise training with or without protein supplementation on cognitive functioning in frail and pre-frail elderly: secondary analysis of a randomized, double-blind, placebo-controlled trial. Mech Ageing Dev. 2014 Mar–Apr;136–137:85–93. 10.1016/j.mad.2013.12.005. PMID: 24374288.24374288
13 Hotting K, Reich B, Holzschneider K, . Differential cognitive effects of cycling versus stretching/coordination training in middle-aged adults. Health Psychol. 2012 Mar;31(2):145–55. doi: 10.1037/a0025371. PMID: 21895371.21895371
14 Komulainen P, Kivipelto M, Lakka T, . Exercise, fitness and cognition–A randomised controlled trial in older individuals: The DR’s EXTRA study. European Geriatric Medicine. 2010;1(5):266–72.
15 Cassilhas RC, Viana VA, Grassmann V, . The impact of resistance exercise on the cognitive function of the elderly. Med Sci Sports Exerc. 2007 Aug;39(8):1401–7. doi: 10.1249/mss.0b013e318060111f. PMID: 17762374.17762374
16 Lachman ME, Neupert SD, Bertrand R, . The effects of strength training on memory in older adults. Journal of Aging & Physical Activity. 2006 Jan;14(1):59–73. PMID: 16648652.16648652
17 Antunes HK, De Mello MT, Santos-Galduroz RF, . Effects of a physical fitness program on memory and blood viscosity in sedentary elderly men. Braz J Med Biol Res. 2015 Sep;48(9):805–12. doi: 10.1590/1414-431X20154529. PMID: 26222648.26222648
18 Satoh M, Ogawa J, Tokita T, . The effects of physical exercise with music on cognitive function of elderly people: Mihama-Kiho project. PLoS One. 2014;9(4):e95230. doi: 10.1371/journal.pone.0095230. PMID: 24769624.24769624
19 Mortimer JA, Ding D, Borenstein AR, . Changes in brain volume and cognition in a randomized trial of exercise and social interaction in a community-based sample of non-demented Chinese elders. J Alzheimers Dis. 2012;30(4):757–66. doi: 10.3233/JAD-2012-120079. PMID: 22451320.22451320
20 Ruscheweyh R, Willemer C, Kruger K, . Physical activity and memory functions: an interventional study. Neurobiology of Aging. 2011 Jul;32(7):1304–19. doi: http://dx.doi.org/10.1016/j.neurobiolaging.2009.08.001. PMID: 19716631.19716631
21 Muscari A, Giannoni C, Pierpaoli L, . Chronic endurance exercise training prevents aging-related cognitive decline in healthy older adults: a randomized controlled trial. Int J Geriatr Psychiatry. 2010 Oct;25(10):1055–64. doi: 10.1002/gps.2462. PMID: 20033904.20033904
22 Lautenschlager NT, Cox KL, Flicker L, . Effect of physical activity on cognitive function in older adults at risk for Alzheimer disease: a randomized trial. JAMA. 2008 Sep 3;300(9):1027–37. doi: 10.1001/jama.300.9.1027. PMID: 18768414.18768414
23 Oken BS, Zajdel D, Kishiyama S, . Randomized, controlled, six-month trial of yoga in healthy seniors: effects on cognition and quality of life. Alternative Therapies in Health & Medicine. 2006 Jan–Feb;12(1):40–7. PMID: 16454146.16454146
24 Okumiya K, Matsubayashi K, Wada T, . Effects of exercise on neurobehavioral function in community-dwelling older people more than 75 years of age. Journal of the American Geriatrics Society. 1996 May;44(5):569–72. PMID: 8617907.8617907
25 Nguyen MH, Kruse A. A randomized controlled trial of Tai chi for balance, sleep quality and cognitive performance in elderly Vietnamese. Clin Interv Aging. 2012;7:185–90. doi: 10.2147/CIA.S32600. PMID: 22807627.22807627
26 Best JR, Chiu BK, Liang Hsu C, . Long-term effects of resistance exercise training on cognition and brain volume in older women: Results from a randomized controlled trial. Journal of the International Neuropsychological Society. 2015 Nov;21(10):745–56. doi: http://dx.doi.org/10.1017/S1355617715000673. PMID: 2015-53115-004.26581787
27 Liu-Ambrose T, Nagamatsu LS, Graf P, . Resistance training and executive functions: a 12-month randomized controlled trial. Archives of Internal Medicine. 2010 Jan 25;170(2):170–8. doi: http://dx.doi.org/10.1001/archinternmed.2009.494. PMID: 20101012.20101012
28 Eggenberger P, Schumacher V, Angst M, . Does multicomponent physical exercise with simultaneous cognitive training boost cognitive performance in older adults? A 6-month randomized controlled trial with a 1-year follow-up. Clin Interv Aging. 2015 17 Aug;10:1335–49. 10.2147/CIA.S87732. PMID: 26316729.26316729
29 Ferreira L, Tanaka K, Santos-Galduroz RF, . Respiratory training as strategy to prevent cognitive decline in aging: a randomized controlled trial. Clin Interv Aging. 2015 20 Mar;10:593–603. 10.2147/CIA.S79560. PMID: 25848235.25848235
30 Colcombe SJ, Erickson KI, Scalf PE, . Aerobic exercise training increases brain volume in aging humans. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2006 Nov;61(11):1166–70. PMID: 17167157.17167157
31 Erickson KI, Voss MW, Prakash RS, . Exercise training increases size of hippocampus and improves memory. Proceedings of the National Academy of Sciences of the United States of America. 2011 Feb 15;108(7):3017–22. doi: http://dx.doi.org/10.1073/pnas.1015950108. PMID: 21282661.21282661
32 Baker LD, Frank LL, Foster-Schubert K, . Aerobic exercise improves cognition for older adults with glucose intolerance, a risk factor for Alzheimer’s disease. J Alzheimers Dis. 2010;22(2):569–79. doi: 10.3233/JAD-2010-100768. PMID: 20847403.20847403
33 Baker LD, Frank LL, Foster-Schubert K, . Effects of aerobic exercise on mild cognitive impairment: a controlled trial. Arch Neurol. 2010 Jan;67(1):71–9. doi: 10.1001/archneurol.2009.307. PMID: 20065132.20065132
34 Smiley-Oyen AL, Lowry KA, Francois SJ, . Exercise, fitness, and neurocognitive function in older adults: the “selective improvement” and “cardiovascular fitness” hypotheses. Annals of Behavioral Medicine. 2008 Dec;36(3):280–91. doi: http://dx.doi.org/10.1007/s12160-008-9064-5. PMID: 18825471.18825471
35 Kramer AF, Hahn S, Cohen NJ, . Ageing, fitness and neurocognitive function. Nature. 1999 Jul 29;400(6743):418–9. PMID: 10440369.10440369
36 Blumenthal JA, Emery CF, Madden DJ, . Long-term effects of exercise on psychological functioning in older men and women. Journal of Gerontology. 1991 Nov;46(6):P352–61. PMID: 1940092.1940092
37 Madden DJ, Blumenthal JA, Allen PA, . Improving aerobic capacity in healthy older adults does not necessarily lead to improved cognitive performance. Psychology & Aging. 1989 Sep;4(3):307–20. PMID: 2803624.2803624
38 Suzuki T, Shimada H, Makizako H, . A randomized controlled trial of multicomponent exercise in older adults with mild cognitive impairment. PLoS One. 2013;8(4):e61483. doi: 10.1371/journal.pone.0061483. PMID: 23585901.23585901
39 Suzuki T, Shimada H, Makizako H, . Effects of multicomponent exercise on cognitive function in older adults with amnestic mild cognitive impairment: a randomized controlled trial. BMC Neurol. 2012;12:128. doi: 10.1186/1471-2377-12-128. PMID: 23113898.23113898
40 Fiatarone Singh MA, Gates N, Saigal N, . The Study of Mental and Resistance Training (SMART) study-resistance training and/or cognitive training in mild cognitive impairment: a randomized, double-blind, double-sham controlled trial. J Am Med Dir Assoc. 2014 Dec;15(12):873–80. doi: 10.1016/j.jamda.2014.09.010. PMID: 25444575.25444575
41 Hildreth KL, Van Pelt RE, Moreau KL, . Effects of pioglitazone or exercise in older adults with mild cognitive impairment and insulin resistance: a pilot study. Dement Geriatr Cogn Dis Extra. 2015 Jan–Apr;5(1):51–63. 10.1159/000371509. PMID: 25852732.25852732
42 van Uffelen JG, Chinapaw MJ, van Mechelen W, . Walking or vitamin B for cognition in older adults with mild cognitive impairment? A randomised controlled trial. British Journal of Sports Medicine. 2008 May;42(5):344–51. doi: http://dx.doi.org/10.1136/bjsm.2007.044735. PMID: 18308888.18308888
43 Lam LC, Chan WC, Leung T, . Would older adults with mild cognitive impairment adhere to and benefit from a structured lifestyle activity intervention to enhance cognition?: a cluster randomized controlled trial. PLoS One. 2015 31 Mar;10(3):e0118173. 10.1371/journal.pone.0118173. PMID: 25826620.25826620
44 Law LL, Barnett F, Yau MK, . Effects of functional tasks exercise on older adults with cognitive impairment at risk of Alzheimer’s disease: a randomised controlled trial. Age Ageing. 2014 Nov;43(6):813–20. doi: 10.1093/ageing/afu055. PMID: 24850540.24850540
45 ten Brinke LF, Bolandzadeh N, Nagamatsu LS, . Aerobic exercise increases hippocampal volume in older women with probable mild cognitive impairment: a 6-month randomised controlled trial. Br J Sports Med. 2015 Feb;49(4):248–54. doi: 10.1136/bjsports-2013-093184. PMID: 24711660.24711660
46 Nagamatsu LS, Chan A, Davis JC, . Physical activity improves verbal and spatial memory in older adults with probable mild cognitive impairment: a 6-month randomized controlled trial. J Aging Res. 2013;2013(861893):861893. doi: 10.1155/2013/861893. PMID: 23509628.23509628
47 Nagamatsu LS, Handy TC, Hsu CL, . Resistance training promotes cognitive and functional brain plasticity in seniors with probable mild cognitive impairment. Arch Intern Med. 2012 Apr 23;172(8):666–8. doi: 10.1001/archinternmed.2012.379. PMID: 22529236.22529236
48 Lam LC, Chau RC, Wong BM, . A 1-year randomized controlled trial comparing mind body exercise (Tai Chi) with stretching and toning exercise on cognitive function in older Chinese adults at risk of cognitive decline. J Am Med Dir Assoc. 2012 Jul;13(6):568 e15–20. doi: 10.1016/j.jamda.2012.03.008. PMID: 22579072.22579072