# Appendix F Cognitive Training Interventions

Appendix Table F1 Characteristics of eligible studies: ACTIVE trial publications

Appendix Table F2 ACTIVE Sample Loss (Based on Initial Enrollment)

Appendix Table F3 Summary risk of bias assessments: ACTIVE trial

Appendix Table F4 Strength of evidence assessments: ACTIVE Trial

Appendix Table F5 Characteristics of eligible studies: other cognitive training trials in adults with normal cognition

Appendix Table F6 Summary risk of bias assessments: other cognitive training trials in adults with normal cognition

Appendix Table F7 Cognitive Training vs. Inactive Comparison, Normal Cognition: Effect Sizes for Miller 2013 (n=84), Klusmann 2010 (n=259), and Carretti 2012 (n=40)

Appendix Figure F1 Cognitive Training vs. Inactive Comparison, Normal Cognition: Plots of Effect Sizes for Miller 2013 (n=84), Klusmann 2010 (n=259), and Carretti 2012 (n=40)

CI=Confidence Interval; RBMT= Rivermead Behavioral Memory Test; FCSRT= Free and Cued Selective Reminding Test; TMT=Trail Making Test

This figure displays a plot of effect sizes and 95% confidence intervals for three studies (Miller 2013, Klusmann 2010, and Carretti 2012) that compare cognitive training to an inactive control in subjects with normal cognition. The results are also displayed in Appendix Table F6. Only four of out 12 tests of memory show a positive Cohen’s d result with the intervention. Effect sizes ranged from 0.33–1.92. Neither of the two tests in the domain of executive, attention, or process speed showed a positive Cohen’s d.

Appendix Table F8 Cognitive Training vs. Active Comparison, Normal Cognition: Effect Sizes for Wolinsky 2013 (n=681)

Appendix Figure F2 Cognitive Training vs. Active Comparison, Normal Cognition: Plots of Effect Sizes for Wolinsky 2013 (n=681)

CI=Confidence Interval; COWAT=Controlled Oral Word Association Test; DVT=Digit Vigilance Test; SDMT= Symbol Digit Modalities Test; TMT=Trail Making Test (Parts A and B); UFOV= Useful Field of View

This figure displays a plot of effect sizes and 95% confidence intervals for the three arms from Wolinksy 2013, a study that compares cognitive training to an active control in subjects with normal cognition. The results are also displayed in Appendix Table F7. All tests are in the domain of executive, attention, or processing speed. Of the 30 analyses included in the plot, only six had a positive Cohen’s D. Effect sizes were generally small with few exceeding 0.5.

Appendix Table F9 Characteristics of eligible studies: other cognitive training trials in adults with MCI

Appendix Table F10 Summary risk of bias assessments: other cognitive training trials in adults with MCI

Appendix Table F11 Cognitive Training vs. Inactive Comparison, MCI: Effect Sizes for Rapp 2002 (n=19)

Appendix Figure F3 Cognitive Training vs. Inactive Comparison, MCI: Plot of Effect Sizes for Rapp 2002 (n=19)

CI=confidence interval; MCI=mild cognitive impairment; n=sample size

This figure displays a plot of effect sizes and 95% confidence intervals for Rapp 2002, a study that compares cognitive training to an inactive control in subjects with MCI. The results are also displayed in Appendix Table F10. For all eight reported tests results, none of the analyses showed a positive Cohen’s D.

Appendix Table F12 Cognitive Training vs. Active Comparison, MCI: Effect Sizes for Herrera 2012 (n=22)

Appendix Figure F4 Cognitive Training vs. Active Comparison, MCI: Plot of Effect Sizes for Herrera 2012 (n=22)

CI=confidence interval; BEM-144=Batterie d’Efficience Mnesique 144; DSM48=Delayed Matching-to-Sample Task; MMSE=Mini-Mental Status Examination; n=sample size

This figure displays a plot of effect sizes and 95% confidence intervals for Herrera 2012, a study that compares cognitive training to an active control in subjects with MCI. The results are also displayed in Appendix Table F11. Six of the seven reported memory tests showed a positive Cohen’s D result. Effect sizes ranged between 1.9 and 3.1. Both of the tests in the executive, attention, processing speed category showed positive Cohen’s D results, with effect sizes up to 4.5.

## References for Appendix F

1 Rebok GW, Ball K, Guey LT, . Ten-year effects of the advanced cognitive training for independent and vital elderly cognitive training trial on cognition and everyday functioning in older adults. Journal of the American Geriatrics Society. 2014 Jan;62(1):16–24. doi: http://dx.doi.org/10.1111/jgs.12607. PMID: 24417410.24417410
2 Rebok GW, Langbaum JB, Jones RN, . Memory training in the ACTIVE study: how much is needed and who benefits? Journal of Aging & Health. 2013 Dec;25(8 Suppl):21S–42S. doi: http://dx.doi.org/10.1177/0898264312461937. PMID: 23103452.23103452
3 Jones RN, Marsiske M, Ball K, . The ACTIVE cognitive training interventions and trajectories of performance among older adults. Journal of Aging & Health. 2013 Dec;25(8 Suppl):186S–208S. doi: http://dx.doi.org/10.1177/0898264312461938. PMID: 23103453.23103453
4 Sisco SM, Marsiske M, Gross AL, . The influence of cognitive training on older adults’ recall for short stories. Journal of Aging & Health. 2013 Dec;25(8 Suppl):230S–48S. doi: http://dx.doi.org/10.1177/0898264313501386. PMID: 24385636.24385636
5 Valdes EG, O’Connor ML, Edwards JD. The effects of cognitive speed of processing training among older adults with psychometrically-defined mild cognitive impairment. Current Alzheimer Research. 2012 Nov;9(9):999–1009. PMID: 22594383.22594383
6 Unverzagt FW, Guey LT, Jones RN, . ACTIVE cognitive training and rates of incident dementia. J Int Neuropsychol Soc. 2012 Jul;18(4):669–77. doi: 10.1017/s1355617711001470. PMID: 22400989.22400989
7 Wolinsky FD, Mahncke H, Vander Weg MW, . Speed of processing training protects self-rated health in older adults: enduring effects observed in the multi-site ACTIVE randomized controlled trial. International Psychogeriatrics. 2010 May;22(3):470–8. doi: http://dx.doi.org/10.1017/S1041610209991281. PMID: 20003628.20003628
8 Wolinsky FD, Vander Weg MW, Martin R, . Does cognitive training improve internal locus of control among older adults? Journals of Gerontology Series B-Psychological Sciences & Social Sciences. 2010 Sep;65(5):591–8. doi: http://dx.doi.org/10.1093/geronb/gbp117. PMID: 20008028.20008028
9 Unverzagt FW, Kasten L, Johnson KE, . Effect of memory impairment on training outcomes in ACTIVE. Journal of the International Neuropsychological Society. 2007 Nov;13(6):953–60. PMID: 17942013.17942013
10 Willis SL, Tennstedt SL, Marsiske M, . Long-term effects of cognitive training on everyday functional outcomes in older adults. JAMA. 2006 Dec 20;296(23):2805–14. PMID: 17179457.17179457
11 Ball K, Berch DB, Helmers KF, . Effects of cognitive training interventions with older adults: a randomized controlled trial. JAMA. 2002 Nov 13;288(18):2271–81. PMID: 12425704.12425704
12 Stine-Morrow EA, Payne BR, Roberts BW, . Training versus engagement as paths to cognitive enrichment with aging. Psychology & Aging. 2014 Dec;29(4):891–906. doi: http://dx.doi.org/10.1037/a0038244. PMID: 25402337.25402337
13 Carretti B, Borella E, Zavagnin M, . Gains in language comprehension relating to working memory training in healthy older adults. Int J Geriatr Psychiatry. 2013 May;28(5):539–46. doi: 10.1002/gps.3859. PMID: 22821686.22821686
14 Miller KJ, Dye RV, Kim J, . Effect of a computerized brain exercise program on cognitive performance in older adults. American Journal of Geriatric Psychiatry. 2013 Jul;21(7):655–63. doi: http://dx.doi.org/10.1016/j.jagp.2013.01.077. PMID: 23602310.23602310
15 Wolinsky FD, Vander Weg MW, Howren MB, . A randomized controlled trial of cognitive training using a visual speed of processing intervention in middle aged and older adults. PLoS ONE [Electronic Resource]. 2013;8(5):e61624. doi: http://dx.doi.org/10.1371/journal.pone.0061624. PMID: 23650501.23650501
16 Cheng Y, Wu W, Feng W, . The effects of multi-domain versus single-domain cognitive training in non-demented older people: a randomized controlled trial. BMC Med. 2012;10:30. doi: 10.1186/1741-7015-10-30. PMID: 22453114.22453114
17 Mortimer JA, Ding D, Borenstein AR, . Changes in brain volume and cognition in a randomized trial of exercise and social interaction in a community-based sample of non-demented Chinese elders. J Alzheimers Dis. 2012;30(4):757–66. doi: 10.3233/JAD-2012-120079. PMID: 22451320.22451320
18 Szelag E, Skolimowska J. Cognitive function in elderly can be ameliorated by training in temporal information processing. Restorative Neurology & Neuroscience. 2012;30(5):419–34. doi: http://dx.doi.org/10.3233/RNN-2012-120240. PMID: 22751354.22751354
19 Evers A, Klusmann V, Schwarzer R, . Improving cognition by adherence to physical or mental exercise: a moderated mediation analysis. Aging Ment Health. 2011 May;15(4):446–55. doi: 10.1080/13607863.2010.543657. PMID: 21500011.21500011
20 Borella E, Carretti B, Riboldi F, . Working memory training in older adults: evidence of transfer and maintenance effects. Psychol Aging. 2010 Dec;25(4):767–78. doi: 10.1037/a0020683. PMID: 20973604.20973604
21 Klusmann V, Evers A, Schwarzer R, . Complex mental and physical activity in older women and cognitive performance: a 6-month randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2010 Jun;65(6):680–8. doi: 10.1093/gerona/glq053. PMID: 20418350.20418350
22 McDougall GJ, Jr., Becker H, Pituch K, . Differential benefits of memory training for minority older adults in the SeniorWISE study. Gerontologist. 2010 Oct;50(5):632–45. doi: http://dx.doi.org/10.1093/geront/gnq017. PMID: 20203096.20203096
23 Park MH, Kwon DY, Seo WK, . The effects of cognitive training on community-dwelling elderly Koreans. Journal of Psychiatric & Mental Health Nursing. 2009 Dec;16(10):904–9. doi: http://dx.doi.org/10.1111/j.1365-2850.2009.01467.x. PMID: 19930364.19930364
24 Slegers K, van Boxtel M, Jolles J. Effects of computer training and internet usage on cognitive abilities in older adults: a randomized controlled study. Aging-Clinical & Experimental Research. 2009 Feb;21(1):43–54. PMID: 19225269.19225269
25 Buiza C, Etxeberria I, Galdona N, . A randomized, two-year study of the efficacy of cognitive intervention on elderly people: the Donostia Longitudinal Study. Int J Geriatr Psychiatry. 2008 Jan;23(1):85–94. doi: 10.1002/gps.1846. PMID: 17530622.17530622
26 Yesavage JA, Friedman L, Ashford JW, . Acetylcholinesterase inhibitor in combination with cognitive training in older adults. J Gerontol B Psychol Sci Soc Sci. 2008 Sep;63(5):P288–94. PMID: 18818443.18818443
27 Lam LC, Chan WC, Leung T, . Would older adults with mild cognitive impairment adhere to and benefit from a structured lifestyle activity intervention to enhance cognition?: a cluster randomized controlled trial. PLoS One. 2015 31 Mar;10(3):e0118173. 10.1371/journal.pone.0118173. PMID: 25826620.25826620
28 Vidovich MR, Lautenschlager NT, Flicker L, . The PACE study: A randomized clinical trial of cognitive activity strategy training for older people with mild cognitive impairment. American Journal of Geriatric Psychiatry. 2015 01 Apr;23(4):360–72. doi:http://dx.doi.org/10.1016/j.jagp.2014.04.002. PMID: 2014736543.24801607
29 Fiatarone Singh MA, Gates N, Saigal N, . The Study of Mental and Resistance Training (SMART) study-resistance training and/or cognitive training in mild cognitive impairment: a randomized, double-blind, double-sham controlled trial. J Am Med Dir Assoc. 2014 Dec;15(12):873–80. doi: 10.1016/j.jamda.2014.09.010. PMID: 25444575.25444575
30 Kwok TC, Bai X, Li JC, . Effectiveness of cognitive training in Chinese older people with subjective cognitive complaints: a randomized placebo-controlled trial. International Journal of Geriatric Psychiatry. 2013 Feb;28(2):208–15. doi: http://dx.doi.org/10.1002/gps.3812. PMID: 22528470.22528470
31 Rojas GJ, Villar V, Iturry M, . Efficacy of a cognitive intervention program in patients with mild cognitive impairment. International Psychogeriatrics. 2013 May;25(5):825–31. doi: http://dx.doi.org/10.1017/S1041610213000045. PMID: 23414646.23414646
32 Buschert VC, Giegling I, Teipel SJ, . Long-term observation of a multicomponent cognitive intervention in mild cognitive impairment. Journal of Clinical Psychiatry. 2012 Dec;73(12):e1492–8. doi: http://dx.doi.org/10.4088/JCP.11m07270. PMID: 23290333.23290333
33 Forster S, Buschert VC, Teipel SJ, . Effects of a 6-month cognitive intervention on brain metabolism in patients with amnestic MCI and mild Alzheimer’s disease. Journal of Alzheimer’s Disease. 2011;26 Suppl 3:337–48. doi: http://dx.doi.org/10.3233/JAD-2011-0025. PMID: 21971473.21971473
34 Herrera C, Chambon C, Michel BF, . Positive effects of computer-based cognitive training in adults with mild cognitive impairment. Neuropsychologia. 2012 Jul;50(8):1871–81. doi: http://dx.doi.org/10.1016/j.neuropsychologia.2012.04.012. PMID: 22525705.22525705
35 Moro V, Condoleo MT, Sala F, . Cognitive stimulation in a-MCI: an experimental study. American Journal of Alzheimer’s Disease & Other Dementias. 2012 Mar;27(2):121–30. doi: http://dx.doi.org/10.1177/1533317512441386. PMID: 22495340.22495340
36 Rapp S, Brenes G, Marsh AP. Memory enhancement training for older adults with mild cognitive impairment: a preliminary study. Aging & Mental Health. 2002 Feb;6(1):5–11. PMID: 1182761711827617